# Summary of Key Informant Calls

## Technical Brief Key Informant Discussion Call #1

Vanderbilt Evidence-based Practice Center Technical Brief: Critical Analysis of the Evidence for Patient Safety Practices in Nursing Home Settings

### Patient Safety Technical Brief Discussion

*Participant names have been redacted from these summaries

#### Introduction to Guiding Questions (GQs)

EPC began the discussion by introducing the first guiding question (GQ) and soliciting for general feedback from the key informants (KIs).

EPC mentioned that the GQs help guide the discussion and would like the KI’s perspective on patient safety issues in the nursing home (NH) setting.

#### Definition of patient safety discussion

EPC inquired how broadly the patient safety construct should be defined. AHRQ defines patient safety broadly and asked the KIs to think about all the potential safety issues in NH settings across the CMS derived quality indicators: staffing, care omission, elder abuse and neglect. She solicited insight from the KIs on what the most silent issues are for NH patient safety.

KI responded that some view patient safety very narrowly and need actual, measurable harm demonstrated rather than missed opportunities and wanted to be really careful about how patient safety is defined in the NH setting and KI agreed.

#### Quality of life (QOL) and person centered care discussion

KI advised the group to not let patient safety issues overwhelm quality of life (QOL) issues and would like to see important QOL issues included under the patient safety definition.

EPC inquired if the KIs are speaking to issues like omitted care or missed care that may not result in an adverse event, but effects QOL, dignity, etc. and KIs agreed that this is extremely important.

KI stated that there are some person-centered measures that capture QOL. Edvardsson, from Norway has done work on developing patient-centered measures, looking at the tradeoff between patient-centered care and safety or adverse events.

EPC mentioned that Rosalie Kane has also written about person-centered care.

EPC stated that one part of the technical brief is to summarize the gaps and point out areas for future research. There is a paucity of quality of life interventions, or person centered interventions so this would be a gap in the literature to highlight for future research.

KI added that NH resident’s subjective experience should be counted here. Research in the NH setting needs to accommodate the experience of the residents in long-term care settings rather than defining quality of life formulaically and the EPC Team agreed.

#### Staff educational training/changing staff behavior discussion

KI added educational programs in long-term care settings as a potential patient safety issue and noted that there is intervention research on educational programs and sustainability of those programs over time and will email some references to the team.

EPC inquired if KI meant there needs to be a different approach to staff training and education that is much more evidence-based in the education or training literature and she agreed.

EPC asked the KIs what they see as some of the significant challenges in changing staff behavior?

KI noted that NH leadership (e.g., director of nursing) is generally inadequately trained in management and is a common problem across NHs. She also noted that nurses who work in NH units also lack management skills (e.g., managing the unit or managing people). There’s a paucity of staff education in managing people.

KIs also noted that frontline staff are generally poorly trained, poorly resourced, and left out of decision making. Another key issue is the trend to hire more LPNs, fewer RNS and even fewer BSNs. If you look at the hospital literature, it suggests that there is a direct correlation to increased mortality, morbidity and costs. LPNs are not trained to assess and, by law in most states, shouldn’t be assessing.

KIs also pointed out that the real patient safety issues are with staff skill mix (e.g., staff skills matched with the skills that are needed in different NH settings with different resident mixes).

KI stated that Nurse Aides have very little training (state’s minimum number of hours, annual infection control, fire safety, compliance training).

#### Overall staff mix/skill levels

KI acknowledged that NH upper level management doesn’t differentiate between CNAs and RNs due to the lack of understanding of differences in skill training and scope of practice between the CNAs and RNs or BSNs.

EPC agreed and added that the scope of practice in NHs is changing. More and more tasks that used to be done by licensed nurses that are now done by nurse aides.

KI would like to see an intervention looking at staff mix in the NH setting. Linda Atkins conducted a staff mix study in hospital settings and those credentials (RN vs. LPN/CAN) actually made a big difference in patient outcomes.

#### Staff turnover/staff to resident ratio issues

KI brought up the issue of inadequate onboarding of staff with minimal orientation.

KI suggested that one possible outcome measure would be employee turnover.

EPC noted that patient to nurse aide ratio is between 10–15 residents to 1 nurse aid and suggested that increasing staffing numbers, education, training, and management of residents are key issues and the KIs agreed.

#### Systems level issues

KI suggested adding systems level issues as a patient safety issue.

EPC Team agreed that when identifying intervention studies in this care setting they are often focused on an isolated aspect of care with one or two key outcomes and that a multifaceted, systems-level intervention is warranted.

EPC agreed that a multicomponent intervention would need to go into a NH and change everything at the same time and implement it.

KI reiterated the key issues are organizational change, including resident case mix changes and staff training.

KI mentioned that the Robert Johnson Foundation funded 5 research groups to conduct a series of nested studies on the Greenhouse program that asked similar questions from different vantage points including large data sets, interviews, MDS and field work. She noted that an article was published in HSR last year on the mixed methods process and challenges, and a special issue that the WJ purchased in Health Services Research that is coming out in early 2016.

#### White House Conference on Aging Brief

The EPC Team inquired if the KIs were familiar with the White House Conference on Aging brief about the changes to improve care and safety in NHs by HHS secretary Sylvia Burwell, specifically the change to ensure that NHs take into consideration the health of residents when making decisions on the kinds of levels of staffing.

KIs mentioned that the federal register report on staffing in NHs actually alluded to that as well.

#### Patient Safety as a broader issue

EPC inquired if the existing measures (e.g., falls, pressures ulcers, weight loss) are not adequate measures of quality or safety in the NH.

KI agreed that the existing patient safety measures should take into consideration quality of life issues (e.g., restraining a resident so that he doesn’t fall and limiting his quality of life/dignity versus letting the resident have the freedom to move around and potentially fall but have quality of life).

#### Hospital care of elderly

KI stated that elderly patient safety is worse in the hospital (e.g., delirium, falls, pressure ulcers), due to hospital staff treating the condition without regard to the age of the patient.

EPC agreed that the hospital treat patients based on the diagnostic codes.

KI added that nurses and physicians tend to see the patient when they’re first admitted as their baseline status instead of how they were functioning two weeks prior to the admission. She also added that most of the infections come from hospitals which are a very different situation than in a nursing home. There’s an infectious disease specialist who is looking at how to keep other residents safe while not completely isolating a resident.

#### Admissions/Transfers to NHs

KI suggested that we look at admissions. Admissions to nursing homes are a huge issue. The transfer of care to NH setting is typically lacking in the information you get, who gets it, how that leads to a care plan, and if there was family involvement in the care planning process.

#### Resident mix changing over time (patient acuity level is higher)

KIs brought up the issue of changing resident mix and the increasing proportion of short and long stay residents. One of the challenges NHs face is how to effectively implement interventions and proper staff training/levels if you have a resident mix with different care needs. The issue of changing resident mix extends to new types of resident populations (e.g., ex-prisoners and parolees, psych patients, AIDS and HIV patients, more trauma patients) leading to higher levels of patient acuity.

The EPC Team agreed and added that this issue underscores the need for higher skilled workforce in NHs and the need for higher staff to resident ratios.

KI added that even among short stay residents, the nature of the population is changing. Residents with hip or knees conditions are being replaced by more medically complex care residents even in the short stay NH settings.

## Technical Brief Key Informant Discussion Call #2

Vanderbilt Evidence-based Practice Center Technical Brief: Critical Analysis of the Evidence for Patient Safety Practices in Nursing Home Settings

### Patient Safety Technical Brief Discussion

#### Introduction to Guiding Questions (GQs)

EPC introduced the GQs to the Key Informants (KIs) and solicited their input based on their experiences and perspectives in the field.

#### Scope/definitions of GQs

KI pointed out that the term patient should be replaced with resident since that is the accepted term in the nursing home (NH) and assisted living communities. She also brought to the team’s attention that the GQs were medically oriented in scope rather than including person-centered quality of life issues.

KI also inquired about dementia in the GQs and stated that roughly half of NH residents have some form of cognitive impairment, many of them with dementia and the comparative figure in assisted living is 40%. She also added that we should be inclusive of the broader category of cognitive impairment, not solely dementia residents in NHs and assisted living facilities.

EPC solicited input from the KIs on how to handle the definition of patient safety for issues that are not measured by adverse events (e.g., quality of life issues for dementia care).

KI inquired if the EPC team was aware of the dementia report that the National Quality Forum did recently? The report provides a conceptual framework for measurements and a literature review on quality measures and the measures that they went through cover the assisted living and NH environments.

#### Gaps in the literature discussion

EPC asked the KIs for input on other salient issues, gaps in the literature or issues for future research that are important to capture in this report.

The KIs suggested that outcomes related to dementia: falls, wandering, use of antipsychotics, and inappropriate medication use that affect cognition should be included.

#### Patient Safety issues in Assisted Living facilities discussion

The EPC team inquired if safety problems for dementia residents are worse in assisted living than they are in NHs.

KI was unsure, but reiterated that NHs are far more sophisticated in tracking patient safety issues (e.g., falls) than assisted living facilities.

KI added that mild cognitive impairment is not the same as early stage dementia and there are many different types of dementia, many of which are diagnosed in error.

EPC agreed that assisted living facilities have a lot of cognitively impaired people and creates additional safety issues.

EPC inquired if there were other safety concerns dementia residents in either assisted living or nursing homes that the EPC team needed to include in the report

KI added swallowing disorders as a significant patient safety issue for Parkinson’s and dementia residents.

#### Dementia

EPC inquired if the issue of medically focused definitions of safety from AHRQ needs to be expanded to include quality of life issues.

KI agreed that resident safety isn’t about medical approaches all of the time. For example, a person with dementia who wanders (as many as 60–80 percent of people with dementia will wander) isn’t particularly a medical issue, but it’s a safety issue. Protocols need to be implemented to address unaccompanied wandering off property or into other resident’s room.

EPC suggested starting the discussion in the area of safety issues for dementia care that are medically related or a central concern for that group of residents in both NHs and assisted living settings.

#### Delirium

KI added delirium as an important patient safety issue. Delirium, knowing whether or not someone has delirium is important. Pain is another clinical measure that is important with delirium residents and their ability to communicate their condition

The EPC team agreed and noted that there’s literature that has repeatedly demonstrated that those with dementia or any type of cognitive impairment are at much higher risk and have poorer clinical outcomes. Accurate treatment of pain, depression, delirium, medication appropriateness, or medication errors should all be considered patient safety issues for the cognitively impaired population and they are going to be at higher risk.

#### Medication errors

EPC inquired if medication error is significant safety concern for assisted living facilities since there is such a low level of licensed nurses.

KI agreed and stated that most of the assisted living facilities used medication aids (not CNAs). Her facilities use LBNs and LPNs, but even then LPNs and LBNs have minimal training. Safety is really a huge issue and it’s getting kind of alarming because the acuity levels are just so high.

#### Regulating assisted living facilities

KI noted that more states including California are looking into regulating assisted living facilities. The Assisted Living Association is trying to be proactive and develop regulations. The CALA association (California Assisted Living Association) has been collecting data precisely to track some of these safety issues. Other organizations are TALA (Texas Assisted Living Association) and the Alpha Group.

#### Grey literature resources discussion

EPC asked the KIs where they look to find interventions to implement on site.

KI mentioned that The Alzheimer’s Association has a series of dementia care practice recommendations that have been around since the 2000’s in the grey literature that you wouldn’t necessarily find in a PubMed search. Dementia care practice recommendations provide an outline on how people can best take care of people with dementia, but how does the facility take that and translate it into an educational program for their staff and how did they implement it during the care planning process? That is where I think the most work probably needs to be done at least in the area of dementia.

KI agreed and suggested looking at the assisted living trade associations (annual meeting, educational conferences). Look at the list of lectures and seminars and sessions they have devoted to safety issues as an indicator of what the trade itself is identifying as problems. And you’d also identify through those trade associations identify their own experts.

#### Change in resident mix for assisted living facilities discussion

The KIs brought up the resident mix is changing for assisted living facilities. NHs used to have residents with more complex medical needs, but now assisted living facilities are seeing an increase in this type of resident and the assisted living industry is aware it is happening, but just beginning to try to set up some regulations to help better deal with this type of complex resident.

#### Staffing mix/ratio/skill level in assisted living facilities and NHs discussion

KI stated that her expertise is mostly with assisted living and the quality of the staff skills is an issue. One of the problems is that assisted living facilities are taking on higher and higher acuity residents that used to be handled in NHs almost exclusively. The assisted living facilities are not staffed with the skill level of a NH or a hospital. The highest skilled staff is the director who might be an RN. Staff mix is mostly LPNs with no skill/competence in assessment, CNAs or aides. Outcomes- in assisted living the outcomes are not tracked- there’s no effort in assisted living to track these outcome measures as a way to improve quality. Assisted living is very primitive when compared to a NH setting.

The KIs added that there is staffing difference between the NHs and assisted living facilities in terms of skill level (e.g., less RNS, aids). Care providers in assisted living don’t have to be certified nursing assistants and it’s unclear how they are trained.

EPC also added that in nursing homes there are some regulations and consensus about what staffing levels should be, but there are little to no regulations in assisted living leading to a lot of assisted living facilities with very poor staff to resident ratios/mix.

KI agreed and noted that the staff ratio varies by state (e.g., the state of California requires assisted living facilities to have one staff for 15 residents) and not all states regulate this.

KI pointed out that assisted living was supposed to be more of a hospitality model for residents to have a gracious life with a little bit of assisted care.

EPC reiterated that in terms of interventions to improve patient safety, everything comes back to staffing (training, staff mix/ratio) and the KIs agreed.

KI added emphasis to the staff skill level and the staffing ratios are just not adequate for the levels of acuity in the NH or assisted living.

#### Person-centered care in assisted living facilities

KI stated that assisted living facilities tend to handle person centered care/dignity/quality of life issues better than NHs because assisted living started out as a hospitality model. Assisted living is an adjunct to independent living and that person-centered model of care has always been imbedded in the programs. The NH model is a nurse dominated model whereas assisted living really isn’t

EPC inquired about the issues that might impede resident safety, including resident assessment and clinical information.

KI responded that assisted living has care plans required in most states, but care plans are loosely put together and not at the level of sophistication found in NHs where monitoring and tracking takes place. The issue with NHs is that they are over regimented (over structured).

KI reiterated that person-centered care is critical to the success of providing good quality of life for residents without or without dementia in assisted living (e.g., if someone likes to seep late they are able to wake up at 10 in the morning instead of 6 in the morning when the shift changes). Knowing the person’s background can help improve their quality of life and quality of care for other residents.

#### End of life care/Hospice

EPC also inquired about quality of end of life care at assisted living facilities and do you view that as a safety issue?

KI stated that the majority of assisted living facilities partner with hospice services. Hospice has its own model, its own rules and expectations

EPC inquired as to when the hospice service is initiated for a resident.

KI stated that the person is typically in a state of decline and will have physician involvement to place the order for hospice services. The family is also involved at this point. Hospice has social workers and grief counselors, and other services for the family. The safety issue would be the staff not having adequate skills. Moving forward, all of our aids need to be CNAs, which would be a new staffing model for assisted living.

## Technical Brief Key Informant Discussion Call #3

Vanderbilt Evidence-based Practice Center Technical Brief: Critical Analysis of the Evidence for Patient Safety Practices in Nursing Home Settings

### Patient safety definition and overview of Guiding Questions (GQs)

The EPC team started out the discussion by introducing the Agency for Healthcare Research and Quality’s (AHRQ) broad definition of patient safety soliciting feedback from the KIs on their views of patient safety in the context of nursing home (NH) settings.

KI stated that it would be challenging to cover every potential patient safety issue in one technical brief.

KI added that safety is not a thing, but a result and it would be hard to imagine safety as a structure.

The EPC team inquired if limiting the report to adverse events is the right course of action. Adverse events discussed in the literature include patient safety issues like falls, pressure sores, weight loss, and medication errors.

EPC reiterated that this report is looking at adverse events as outcomes.

KI added that from a hospital perspective, dealing with infections and reporting infection outcomes (e.g., surgical site infections), that we really don’t know preventability. We know what our rate should be compared to our peer hospitals and can examine process failures and adherence, but we may not know direct causality or preventability. Several patient safety issues of concern in a post-acute care facility (e.g., NH, skilled nursing facility [SNF], assisted living) would be the acquired urinary tract infection (UTI), respiratory tract infection, and gastroenteritis, level of vaccinated workers, hand washing practices, and safe injection practice. Some of these are measurable (e.g., process, outcome measures).

EPC also inquired if preventability can be done in a nursing home not just in a hospital setting and KI stated that there’s pretty good evidence in hospitals that depending on the kind of anesthesia used during an operation it reduces or increases the likelihood that specific types of patients have delirium post-surgically. Now what are the causes of delirium and do they arise while people are in nursing homes and can they be addressed and prevented? It’s likely that it’s possible to the extent that it’s actually defined and documented.

EPC inquired if hospitalizations and burdensome transitional care should be encompassed under patient safety?

KI replied that there are a certain strata of patients with re-hospitalizations for hip fracture rehab which is a very different issue than re-hospitalizations of a NH resident with multiple chronic comorbidities and multiple medications. Those patients present a different set of clinical problems and a different set of clinical rates. Both can potentially be prevented and it depends of how you want to do that.

### Scope of patient safety Issues covered in the report

KI stated that patient quality is a big issue and is subset of patient safety and need to define it in advance and focus on some of the most important patient safety areas because you can’t cover everything and the EPC team agreed. She also pointed out that the literature on even one of these patient safety issues could be a whole technical brief in itself.

EPC inquired what salient issues are the most important to focus on in this report and KI stated that pressure ulcers, infection, psychotropic drug use, weight loss, activities of daily living (ADL) decline, incontinence, and pain are the main patient safety issues. Re-hospitalization could be included, but really should be in a separate report and the other KIs agreed.

EPC stated that some of the issues that have come up in our previous KI calls were aspects of safety and quality that have not been traditionally captured by the Nursing Home compare quality measures. She inquired if there other measures that are not necessarily clinical outcomes, but other types of outcomes that we should include in this report?

KI suggested adding the issue of staffing (e.g., low staffing levels lead to bad safety practice) and the EPC team noted that this is an issue that is cross-cutting over all patient safety issues.

The EPC team inquired if it is important to include quality of life or resident-centered care issues in the report (e.g., non-clinical events, hospital readmissions).

KI suggested to not include quality of life under the concept of patient safety to help narrow the scope of how we are defining patient safety and the other KIs agreed that it would broaden the scope too far for this report.

KI also suggested limiting the report by not taking on assisted living and just point out the issues around assisted living and KI agreed that the report needs to focus on the medical safety issues where there’s some institutional and societal obligation to keep people safe and the EPC team agreed.

### Antimicrobial stewardship and infection control

KI noted that particularly in long-term care facilities, there is a need for antimicrobial stewardship for all uses of drug resistant organism infections (e.g., C. Diff.) and KI agreed that antimicrobial stewardship is a significant patient safety issue. The complications associated with antibiotic use in the face of infection whether they’re asymptomatic or even marginally symptomatic implies for the overall burden in the facility and its risk of increase in population rates of multi-organ resistant bacteria. There is reasonably good evidence to suggest that some hospitals and NHs, as they transfer patients back and forth, became pretty significant reservoirs of drug resistant organism infections that have the adverse effect on everyone else that passes through those hospitals and NHs in terms of their increased risk of a drug resistant organism diagnosis subsequently and the role of antibiotic use on the context of that is a significant issue. They might be viewed as medication errors but they are actually not a classic medication error.

EPC inquired if hospitals are better at infection control and prevention than NHs and KI responded that hospital programs exist around the appropriateness of antimicrobials, in terms of indication (e.g., ensuring narrow spectrum antibiotics or treating colonization and appropriate diagnostic testing upfront) so there is not unnecessary use of antibiotics. The science is just starting as far as what interventions work, what is effective and that’s just in acute care settings.

### Short and long stay resident safety issues

KI inquired about patient safety issues in short and long stay NH populations. He noted that there is rising pressure surrounding preferred provider selection due to penalties from Medicare Advantage and the insurer’s role in the contracting process. The differentiation between short and long stay is probably going to only be further differentiated in time and the safety issues for e.g., Alzheimer’s care unit in assisted living. There are increasingly more post-acute settings that are more like extensions of hospitals and there is an expectation that those people going to post-acute are intending to go home. The long stay patients, they live there. It does become a quality of life issue in terms of whether they have more autonomy and control and are willing to take the risk of some adverse events. It will never be 100% clear but to the extent that quality or safety, it is multifactorial and those factors are not correlated. It’s even more so as you looked at that across short stay and long stay populations.

EPC reiterated that he was referring to as quality of life for long-term stay residents that the patient safety issues might not be accurately measure quality and the KIs agreed.

### Increasing number of impaired assisted living residents

EPC stated that assisted living is seeing an increase in more impaired residents, but the staff skill level and staff ratios in assisted living facilities are lower than NHs. He inquired if that poses bigger safety issues/problems in assisted living than in NHs?

KI agreed and stated that the general trend has been that people in assisted living are more impaired than they were 10 years ago and people who are in assisted living now are people who were in NHs 10 or 15 years ago.

The KIs also noted that outcomes aren’t tracked in assisted living facilities like they are in NHs and added that the median tenure in assisted living is only like 9–12 months before either dying or graduating to the NH.

### Palliative Care and Hospice

KI noted another issue for both short term and long term care is the issue of residents in the facility for palliative care or hospice. When do you stop aggressive treatment and preventing infections during end of life care and questioned if the EPC team thought that would be considered a safety issue.

EPC agreed that this could be a safety issue for end of life residents that may get excessive treatment that could lead to adverse events and KI added that people who come directly from hospital units to hospice units (in NHs and SNFs) across the country is a very high and fast growing number and that it’s an issue. He also added that Medicare Advantage (MA) patients typically enter hospice services about 5 days earlier than other patients.

### Polypharmacy and medication reconciliation issues

KI brought up polypharmacy as a patient safety issue and stated that, for example, SNF patients take 15 medications on average. He also noted that some NH residents are treated for multiple comorbid conditions that require 3–4 medications per each condition resulting in high medication counts.

EPC agreed and noted that there are long-term residents taking medications for indications that no longer exist because due to lack of medication reconciliation would be considered a patient safety issue.

### Staffing

KI brought up the issue of regarding quality improvement programs and intervention studies on staffing that are conducted in facilities that don’t have adequate staffing so you don’t see the results and suggested that a clinical trial on RN staffing was needed to demonstrate that almost all these patient safety outcomes might be better if you had RN staffing and EPC agreed that there are muted effects on any intervention because of staffing limitations.

KI suggested looking at staffing in the context of these outcomes and EPC agreed and mentioned that the issue of staffing, both in terms of number and kind of skill set, has come up several times as like an overarching issue that impacts all patient safety issues.

KI agreed and stated that the majority of staffing studies in hospital settings show that higher RN staffing makes a bigger difference in patient safety than higher total staffing.

### Future Research Needs

EPC inquired if the KIs had any topics for potential future research in the NH setting.

KI suggested three future research topics:

1. What’s the benefit of an extra hour of therapy?
2. Antibiotic stewardship affects both the short stay and the long stay in terms of the proclivity of a facility to actually engage in antimicrobial prescription and there is little evidence in the NH setting about how that’s used what the positive effects of reducing or more rationalizing the use of antimicrobials might be.
3. What’s the effect of more rationalized medication prescription and de-prescribing medications in very elderly or very frail NH residents?

### Gray Literature

KI suggested that there’s one area of evidence to look at which is the Quality Improvement Organizations (QIO) initiative about quality improvement which often does not lead to publications, but sometimes leads to reports and the EPC team agreed that this would be a good source for gray literature. KI also suggested reaching out to individuals in Denver who run the CMS QIO program across nursing homes.