# Summary and Implications

Scientific advances in recent decades have led to the discovery of genetic abnormalities that may explain the reasons for many developmental disability (DD) cases. A large number of genetic tests have been developed and adopted in clinical practice. These tests are used to differentiate well-defined DD syndromes (e.g., fragile X syndrome, Rett syndrome) or, more commonly, to establish an etiologic diagnosis for unexplained intellectual disability (ID), autism spectrum disorder (ASD), or global developmental delay (GDD). For this Technical Brief, we identified 672 genetic tests for 11 DD categories using the National Center for Biotechnology Information’s Genetic Testing Registry (GTR) database. These tests employ a broad range of methods, including next-generation sequencing, Sanger sequence analysis, microarray, comparative genomic hybridization, single nucleotide polymorphism detection, multiplex ligation-dependent probe amplification, and other polymerase chain reaction–based tests. These tests analyze a single gene, a chromosome, a chromosomal region, or the whole genome or exome.

Our search identified a single U.S. Food and Drug Administration (FDA)-cleared commercial test kit. All other 672 tests are laboratory-developed tests (LDTs). These LDTs are offered by 63 laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 in 29 States. Patients in some States may not have access to certain LDTs. FDA does not actively regulate LDTs at this time; however, on October 3, 2014, FDA published two draft guidance documents regarding oversight of LDTs. The proposed policy change has some significant implications for the LDTs we compiled in this Technical Brief. When The FDA guidance documents are finalized, we will have a better chance to evaluate how LDTs will be regulated in the future.

As genetic tests have become increasingly available, payers have observed a rapid diffusion of these tests in health care. Some tests (e.g., microarray-based comparative genomic hybridization [aCGH]) have been recommended by professional groups as first-tier diagnostic tests for DDs. The proposed benefits of genetic testing include providing an improved sense of empowerment for patient families, refining treatment options, providing prognosis, preventing comorbidities, avoiding unnecessary diagnostic tests, providing recurrence-risk-based counseling, and improving access to needed support or services. However, these proposed benefits need to be validated by clinical studies.

One major goal of this Technical Brief is to identify existing evidence for addressing the clinical utility of genetic tests for DDs. To achieve the goal, we thoroughly scanned medical literature (see Table 12 below for a summary of this effort). We focused on evidence directly linking genetic testing to changes in health outcomes. However, our search did not identify any study—randomized or nonrandomized—in that category. We consider this a major gap that needs to be filled by future research. Randomized controlled trials (RCTs) and well-designed nonrandomized studies that directly compare health outcomes for use versus no use of the tests is the ideal type of study for addressing clinical utility. However, conducting these studies, particularly RCTs, can be difficult for various practical reasons. Because the genetic testing area changes so quickly, the test being studied may become obsolete even before long-term data are available. Other practical challenges for conducting clinical utility trials also exist, such as difficulty in patient recruitment (particularly for rare disorders) and high expense associated with the studies. Regardless of these challenges, it may still be feasible to design and execute clinical utility trials for certain tests and disorders, and we encourage researchers to make an effort in that direction.

Table 12 Evidence gap

Domain | Ideal Evidence | Helpful Evidence | Number of Studies Identified
Clinical utility | RCTs directly evaluating if use of the test affects clinical outcomes | | 0
Clinical utility | | Non-RCT studies directly evaluating whether use of the test affects clinical outcomes | 0
Clinical utility | | Studies that evaluate the impact of testing on clinical management or family decisions | 8
Clinical utility | | Studies that evaluate patients or families’ preference for genetic testing | 2
Clinical utility | | Diagnostic case series | 129
Clinical validity^*^ | Cohort studies that evaluate the test’s diagnostic accuracy using phenotype or other acceptable diagnostic standards as reference methods | | 0
Clinical validity^*^ | | Case-control studies that evaluate the test’s diagnostic accuracy | 1
Analytic validity | Case-control studies using appropriately validated samples to evaluate the test’s analytic accuracy | | 15
Analytic validity | | Case series that study analytic performance | 5
Analytic validity | Studies reporting on the findings of external proficiency testing programs | | 0
Analytic validity | Bench studies that evaluate a test’s repeatability, reproducibility, and other performance characteristics | | 0
Economic issue | Cost-effectiveness analysis | | 0
Economic analysis | | Economic-impact studies, cost reports | 0
Ethical, legal, social impact | Surveys; reports of consensus-based opinions | | 0

* Given that most of the genetic tests relevant to this report are rarely used in isolation to establish a clinical diagnosis, the number of studies that report clinical validity (i.e., diagnostic accuracy) is expected to be small.

RCT=randomized controlled trial

Besides searching clinical trials, we also searched for other types of evidence that may contribute to establishing an indirect linkage between genetic testing and health outcomes. We identified a small number of studies assessing genetic tests’ value perceived by families affected by DDs or addressing the impact of genetic testing on clinical management or family decisions. This type of study enhances our understanding of genetic tests’ potential to cause changes in health outcomes (e.g., psychosocial outcomes). For example, one survey we identified reported that some parents of children with DD considered a clinical diagnosis (e.g., autism) more useful a label than a rare, specific etiological diagnosis.43 The intensity of their need for an etiologic diagnosis was reported to diminish over time. A few case series we identified reported changes being made in patient management due to the findings of genetic tests. More studies should be performed to investigate these important issues, particularly parents’ views on the importance of determining etiology and how to counsel them on the value of etiologic evaluation.

Given that most of the genetic tests relevant to this report are rarely used in isolation to establish a clinical diagnosis, we only identified a single case-control study that addressed clinical validity (i.e., diagnostic accuracy). Our literature search identified 20 studies addressing analytic validity issues. Most of these studies validated the analytic performance of a newly developed test, reporting on the test’s sensitivity, specificity, predictive values, concordance, or repeatability. The findings of these studies of new tests need to be further validated in future research.

We identified a large number (129) of case series that reported on the diagnostic yield of a genetic test. These case series constitute the largest portion of the evidence base we report in this Technical Brief. However, no consensus has been reached on the usefulness of diagnostic yield studies in assessing a genetic test’s clinical utility (impact on health outcomes). Although diagnostic yield indicates the percentage of patients being tested who ultimately reach a diagnosis, it does not confirm whether the diagnoses reached are correct. Improved diagnostic yield may have an impact on patient management because some condition-specific management (e.g., obesity prevention programs for DD patients at higher risk for developing the comorbidity) cannot be initiated without a specific diagnosis (e.g., an etiologic diagnosis revealing a patient carries a genetic variant associated with obesity). However, patient management changes based on the testing may not necessarily lead to improved health outcomes.

In the context of DD care, genetic testing is often used to establish an etiologic diagnosis rather than establish a clinical diagnosis. However, researchers may not always agree on whether a genetic aberration (e.g., certain type of copy number variants) is “causal,” “pathogenic,” or “clinically significant.” Several public information sources exist to facilitate the identification of causal genetic aberrations. These sources include the National Center for Biotechnology Information; the International Standards for Cytogenomic Arrays; American College of Medical Genetics and Genomics Practice Guidelines; the University of California, Santa Cruz, Genome Browser; the Database of Genomic Variants; and the Genoglyphix Chromosome Aberration Database. However, the existence of these databases does not completely eliminate the uncertainty in certain genetic aberrations’ causal role in DDs. A more robust framework for evaluating which variants play a role in disease and are relevant to patient care is needed.193 The uncertainty in the current databases discounts some diagnostic-yield studies’ validity. Ongoing efforts, such as the National Institutes of Health–funded Clinical Genome Resource (ClinGen), may provide valuable information for identifying clinically relevant genetic variants.193

For this Technical Brief, we also searched for studies that addressed cost, ethical, legal, and social issues related to using genetic tests for DDs. However, we did not identify any economic studies performed in the U.S. context. We did not identify any empirical research on legal, and social issues specifically related to genetic testing for DDs. As a result, the impact of genetic testing in those areas remains unclear.

Table 12 below summarizes the evidence gaps we previously discussed. We referred to several guidance documents published by the Agency for Healthcare Research and Quality and the Cochrane Library to determine the types of evidence required for addressing a genetic test’s clinical utility.36,194,195 As the table indicates, evidence that directly or indirectly supports genetic testing’s clinical utility is generally thin. Significant investment in research to fill the gaps may be needed. Additionally, the effectiveness of genetic testing (e.g., its accuracy, impact on health outcomes) may be affected by who orders the tests or who interprets the test results. Our literature search did not identify any comparison study that address this concern, which is another gap that needs to be filled by future research.

This Technical Brief has several limitations. First, we primarily relied on GTR to identify genetic tests. Because the GTR data were voluntarily submitted by test providers, genetic tests that were not reported to GTR are not captured by this brief. Although the GTR database is arguably one of the most comprehensive sources on genetic tests, how well the tests we identified represent the whole landscape of genetic testing for DDs is not clear.

Second, within the timeframe of this Technical Brief, we were not able to independently verify the accuracy of the GTR data submitted by test providers. Although the GTR implements a solid data quality assurance program,38 we are not certain about the program’s effectiveness. Readers of this report should use caution when they interpret the GTR data we collected.

Third, DDs include a large number of disorders. This Technical Brief focuses only on some common DD conditions or syndromes based on the need of the key stakeholders for this project. Genetic tests for many rare DD syndromes are not within the scope of the brief. The findings of this Technical Brief should be interpreted as only applying to the DD conditions included in the report.

Fourth, this Technical Brief is intended to collect basic information on genetic tests for DDs. It is not a systematic review. Although we performed a systematic search for evidence that potentially addresses genetic tests’ clinical utility, we did not comprehensively evaluate the strength of evidence. To have a more in-depth understanding of how well the evidence has addressed the clinical utility issues, a series of systematic reviews may be needed.

Despite these limitations, this Technical Brief provides useful information for understanding the current landscape of genetic testing for DDs. The evidence gaps identified will help guide future research to generate the most needed evidence for addressing genetic tests’ clinical utility in the context of DD care.