# References

1 National Center on Birth Defects and Developmental Disabilities (NCBDDD). Facts about developmental disabilities. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2013. Dec. 26. http://www.cdc.gov/ncbddd/developmentaldisabilities/facts.html. Accessed 2014 Apr 01.
2 Boyle CA, Boulet S, Schieve LA, et al. Trends in the prevalence of developmental disabilities in US children, 1997–2008. Pediatrics. Jun. 2011;127(6):1034-42. [pmid: 21606152].
3 Moeschler JB, Shevell M. Committee on Genetics. Comprehensive evaluation of the child with intellectual disability or global developmental delays. Pediatrics. Sep. 2014;134(3):e903-18. [pmid: 25157020].
4 Shevell M, Ashwal S, Donley D, et al. Practice parameter: evaluation of the child with global developmental delay: report of the Quality Standards Subcommittee of the American Academy of Neurology and The Practice Committee of the Child Neurology Society. Neurology. Feb. 11. 2003;60(3):367-80. [pmid: 12578916].
5 Roeleveld N, Zielhuis GA, Gabreels F. The prevalence of mental retardation: a critical review of recent literature. Dev Med Child Neurol. Feb. 1997;39(2):125-32. [pmid: 9062428].
6 Schalock RL, Luckasson RA, Shogren KA, et al. The renaming of mental retardation: understanding the change to the term intellectual disability. Intellect Dev Disabil. Apr. 2007;45(2):116-24. [pmid: 17428134].
7 Frequently asked questions on intellectual disability. Washington (DC). American Association on Intellectual and Developmental Disabilities (AAIDD). http://aaidd.org/intellectual-disability/definition/faqs-on-intellectual-disability#.VCBG9Xl0wUR. Accessed 2014 Sep 22.
8 What causes IDDs?. Bethesda (MD). Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD). 2012. Nov. 30. http://www.nichd.nih.gov/health/topics/idds/conditioninfo/Pages/causes.aspx. Accessed 2014 Sep 22.
9 Intellectual disability. Elk Grove Village (IL). American Academy of Pediatrics. 2014. Sep. 02. http://www.healthychildren.org/English/health-issues/conditions/developmental-disabilities/pages/Intellectual-Disability.aspx. Accessed 2014 Sep 22.
10 Developmental Disabilities Monitoring Network Surveillance Year 2010 principal investigators, Centers for Disease Control and Prevention (CDC). Prevalence of autism spectrum disorder among children aged 8 years - autism and developmental disabilities monitoring network, 11 sites, United States, 2010. Morb Mortal Wkly Rep Surveill Summ. Mar. 28. 2014;63(2):1-21. [pmid: 24670961].
11 Freitag CM, Staal W, Klauck SM, et al. Genetics of autistic disorders: review and clinical implications. Eur Child Adolesc Psychiatry. Mar. 2010;19(3):169-78. [pmid: 19941018].
12 State MW. The genetics of child psychiatric disorders: focus on autism and Tourette syndrome. Neuron. Oct. 21. 2010;68(2):254-69. [pmid: 20955933].
13 Volkmar F, Siegel M, Woodbury-Smith M, et al. Practice parameter for the assessment and treatment of children and adolescents with autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. Feb. 2014;53(2):237-57. [pmid: 24472258].
14 Moeschler JB. Medical genetics diagnostic evaluation of the child with global developmental delay or intellectual disability. Curr Opin Neurol. Apr. 2008;21(2):117-22. [pmid: 18317267].
15 Shevell M, Ashwal S, Donley D, et al. Practice parameter: evaluation of the child with global developmental delay: report of the Quality Standards Subcommittee of the American Academy of Neurology and the Practice Committee of the Child Neurology Society [slide set]. St. Paul (MN). American Academy of Neurology. 2003. 60 p.
16 McDonald L, Rennie A, Tolmie J, et al. Investigation of global developmental delay. Arch Dis Child. Aug. 2006;91(8):701-5. [pmid: 16861488].
17 Kaufman L, Ayub M, Vincent JB. The genetic basis of non-syndromic intellectual disability: a review. J Neurodev Disord. Dec. 2010;2(4):182-209. [pmid: 21124998].
18 Rauch A, Hoyer J, Guth S, et al. Diagnostic yield of various genetic approaches in patients with unexplained developmental delay or mental retardation. Am J Med Genet A. Oct. 1. 2006;140(19):2063-74. [pmid: 16917849].
19 Schaefer GB, Mendelsohn NJ. Clinical genetics evaluation in identifying the etiology of autism spectrum disorders: 2013 guideline revisions. Genet Med. May. 2013;15(5):399-407. [pmid: 23519317].
20 Michelson DJ, Shevell MI, Sherr EH, et al. Evidence report: genetic and metabolic testing on children with global developmental delay: report of the Quality Standards Subcommittee of the American Academy of Neurology and the Practice Committee of the Child Neurology Society. Neurology. Oct. 25. 2011;77(17):1629-35. [pmid: 21956720].
21 Miller DT, Adam MP, Aradhya S, et al. Consensus statement: chromosomal microarray is a first-tier clinical diagnostic test for individuals with developmental disabilities or congenital anomalies. Am J Hum Genet. May. 14. 2010;86(5):749-64. [pmid: 20466091].
22 Mroch AR, Flanagan JD, Stein QP. Solving the puzzle: case examples of array comparative genomic hybridization as a tool to end the diagnostic odyssey. Curr Probl Pediatr Adolesc Health Care. Mar. 2012;42(3):74-8. [pmid: 22325475].
23 Coulter ME, Miller DT, Harris DJ, et al. Chromosomal microarray testing influences medical management. Genet Med. Sep. 2011;13(9):770-6. [pmid: 21716121].
24 Riggs E, Wain K, Riethmaier D, et al. Chromosomal microarray impacts clinical management. Clin Genet. Feb. 2013;85(2):147-53. Epub 2013 Feb 21. [pmid: 23347240].
25 Saam J, Gudgeon J, Aston E, et al. How physicians use array comparative genomic hybridization results to guide patient management in children with developmental delay. Genet Med. Mar. 2008;10(3):181-6. [pmid: 18344707].
26 Turner G, Boyle J, Partington MW, et al. Restoring reproductive confidence in families with X-linked mental retardation by finding the causal mutation. Clin Genet. Feb. 2008;73(2):188-90. [pmid: 18070138].
27 Manning M, Hudgins L. Array-based technology and recommendations for utilization in medical genetics practice for detection of chromosomal abnormalities. Genet Med. Nov. 2010;12(11):742-5. [pmid: 20962661].
28 What is the comparative effectiveness of genetic and other diagnostic tests to identify and treat intellectual and developmental disabilities caused by genetic mutations in post-natal to early childhood populations?. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2013. Oct. 26. http://effectivehealthcare.ahrq.gov/submit-a-suggestion-for-research/read-suggested-topics-for-research/?pageAction=view&topicID=594&source=current. Accessed 2014 Jun 24.
29 Special report: aCGH for the genetic evaluation of patients with developmental delay/mental retardation or autism spectrum disorder (Structured abstract). Health Tech Assess Database. 2008;(1). http://onlinelibrary.wiley.com/o/cochrane/clhta/articles/HTA-32010000222/frame.html.
30 Topic triage cover sheet: Genetic testing for developmental diseases. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2012. Mar. 6. 5 p.
31 Jordan BR, Tsai DF. Whole-genome association studies for multigenic diseases: ethical dilemmas arising from commercialization--the case of genetic testing for autism. J Med Ethics. Jul. 2010;36(7):440-4. [pmid: 20558435].
32 Secretary’s Advisory Committee on Genetics, Health, and Society (SACGHS). U.S. system of oversight of genetic testing: a response to the charge of the Secretary of Health and Human Services. Washington (DC). Department of Health & Human Services. Apr. 2008:276. http://www4.od.nih.gov/oba/SACGHS/reports/SACGHS_oversight_report.pdf.
33 Sun F, Bruening W, Uhl S, et al. Quality, regulation and clinical utility of laboratory-developed molecular tests. (Prepared by ECRI Institute Evidence-based Practice Center under Contract No. 290-2007-1063 I). Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). May. 19. 2010:217. http://www.cms.gov/determinationprocess/downloads/id72TA.pdf.
34 U.S. Food and Drug Administration (FDA), Center for Biologics Evaluation and Research. Draft guidance for industry, Food and Drug Administration staff, and clinical laboratories: FDA notification and medical device reporting for laboratory developed tests (LDTs). Silver Spring (MD). U.S. Food and Drug Administration (FDA). Oct. 3. 2014:28. http://www.fda.gov/ucm/groups/fdagov-public/%40fdagov-meddev-gen/documents/document/ucm416684.pdf.
35 U.S. Food and Drug Administration (FDA), Center for Biologics Evaluation and Research. Draft guidance for industry, Food and Drug Administration staff, and clinical laboratories: framework for regulatory oversight of laboratory developed tests (LDTs). Silver Spring (MD). U.S. Food and Drug Administration (FDA). Oct. 3. 2014:41. http://www.fda.gov/downloads/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/UCM416685.pdf.
36 Sun F, Bruening W, Erinoff E, et al. Addressing challenges in genetic test evaluation. Evaluation frameworks and assessment of analytic validity Methods research report. (Prepared by the ECRI Institute Evidence-based Practice Center under Contract No. HHSA 290-2007-10063-I.) AHRQ publication no. 11-EHC048-EF. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Jun. 2011:107. http://www.ncbi.nlm.nih.gov/books/NBK56750/pdf/TOC.pdf.
37 Sun F, Schoelles KM, Coates VH. Assessing the utility of genetic tests. J Ambul Care Manage. Jul–Sep. 2013;36(3):222-32. [pmid: 23748269].
38 Rubinstein WS, Maglott DR, Lee JM, et al. The NIH genetic testing registry: a new, centralized database of genetic tests to enable access to comprehensive information and improve transparency. Nucleic Acids Res. Jan. 2013;41:D925-35. [pmid: 23193275].
39 Evaluation of automatic class III designation for Affymetrix CytoScan Dx Assay decision summary. K130313. Silver Spring (MD). U.S. Food and Drug Administration. 44. http://www.accessdata.fda.gov/cdrh_docs/reviews/K130313.pdf.
40 Ellison JW, Ravnan JB, Rosenfeld JA, et al. Clinical utility of chromosomal microarray analysis. Pediatrics. Nov. 2012;130(5):e1085-e1095. [pmid: 23071206].
41 Iglesias A, Anyane-Yeboa K, Wynn J, et al. The usefulness of whole-exome sequencing in routine clinical practice. Genet Med. 2014. Jun. 5. Epub ahead of print. [pmid: 24901346].
42 Bruno DL, Ganesamoorthy D, Schoumans J, et al. Detection of cryptic pathogenic copy number variations and constitutional loss of heterozygosity using high resolution SNP microarray analysis in 117 patients referred for cytogenetic analysis and impact on clinical practice. J Med Genet. Feb. 2009;46(2):123-31. [pmid: 19015223].
43 Makela NL, Birch PH, Friedman JM, et al. Parental perceived value of a diagnosis for Intellectual Disability (ID): A qualitative comparison of families with and without a diagnosis for their child’s ID. Am J Med Genet A. Nov. 2009;149(11):2393-402. [pmid: 19842198].
44 Costain G, Chow EW, Ray PN, et al. Caregiver and adult patient perspectives on the importance of a diagnosis of 22q11.2 deletion syndrome. J Intellect Disabil Res. Jun. 2012;56(6):641-51. [pmid: 22142442].
45 Amiet C, Couchon E, Carr K, et al. Are there cultural differences in parental interest in early diagnosis and genetic risk assessment for autism spectrum disorder?. Front Pediatr. 2014;2:32. [pmid: 24795872].
46 Jiao Y, Chen R, Ke X, et al. Predictive models for subtypes of autism spectrum disorder based on single-nucleotide polymorphisms and magnetic resonance imaging. Adv Med Sci. Dec. 1. 2011;56(2):334-42. [pmid: 22037176].
47 Srivastava S, Cohen JS, Vernon H, et al. Clinical whole exome sequencing in child neurology practice. Ann Neurol. 2014. Oct. http://dx.doi.org/10.1002/ana.24226.
48 Kalman LV, Tarleton JC, Percy AK, et al. Development of a genomic DNA reference material panel for Rett syndrome (MECP2-related disorders) genetic testing. J Mol Diagn. Mar. 2014;16(2):273-9. [pmid: 24508304].
49 Inaba Y, Schwartz CE, Bui QM, et al. Early detection of fragile X syndrome: Applications of a novel approach for improved quantitative methylation analysis in venous blood and newborn blood spots. Clin Chem. Jul. 2014;60(7):963-73. [pmid: 24778142].
50 Hayes JL, Tzika A, Thygesen H, et al. Diagnosis of copy number variation by Illumina next generation sequencing is comparable in performance to oligonucleotide array comparative genomic hybridisation. Genomics. Sep. 2013;102(3):174-81. [pmid: 23598253].
51 Stofanko M, Han JC, Elsea SH, et al. Rapid and inexpensive screening of genomic copy number variations using a novel quantitative fluorescent PCR method. Dis Markers. 2013;35(6):589-94. [pmid: 24288428].
52 Stofanko M, Goncalves-Dornelas H, Cunha PS, et al. Simple, rapid and inexpensive quantitative fluorescent PCR method for eetection of microdeletion and microduplication syndromes. PLoS ONE. Apr. 19. 2013;8(4):e61328. [pmid: 23620743].
53 Koshimizu E, Miyatake S, Okamoto N, et al. Performance comparison of bench-top next generation sequencers using microdroplet PCR-based enrichment for targeted sequencing in patients with autism spectrum disorder. PLoS ONE. Sep. 16. 2013;8(9):e74167. [pmid: 24066114].
54 Lafauci G, Adayev T, Kascsak R, et al. Fragile X screening by quantification of FMRP in dried blood spots by a luminex immunoassay. J Mol Diagn. Jul. 2013;15(4):508-17. [pmid: 23660422].
55 Curtis-Cioffi KM, Rodrigueiro DA, Rodrigues VC, et al. Comparison between the polymerase chain reaction-based screening and the southern blot methods for identification of fragile X syndrome. Genet Test Mol Biomar. Nov. 1. 2012;16(11):1303-8. [pmid: 23101592].
56 Juusola JS, Anderson P, Sabato F, et al. Performance evaluation of two methods using commercially available reagents for PCR-based detection of FMR1 mutation. J Mol Diagn. Sep. 2012;14(5):476-86. [pmid: 22765921].
57 Lessard M, Chouiali A, Drouin R, et al. Quantitative measurement of FMRP in blood platelets as a new screening test for fragile X syndrome. Clin Genet. Nov. 2012;82(5):472-7. [pmid: 21992468].
58 Bernardini L, Alesi V, Loddo S, et al. High-resolution SNP arrays in mental retardation diagnostics: how much do we gain?. Eur J Hum Genet. Feb. 2010;18(2):178-85. [pmid: 19809473].
59 Chen L, Hadd A, Sah S, et al. An information-rich CGG repeat primed PCR that detects the full range of fragile X expanded alleles and minimizes the need for southern blot analysis. J Mol Diagn. Sep. 2010;12(5):589-600. [pmid: 20616364].
60 Filipovic-Sadic S, Sah S, Chen L, et al. A novel FMR1 PCR method for the routine detection of low abundance expanded alleles and full mutations in fragile X syndrome. Clin Chem. Mar. 2010;56(3):399-408. [pmid: 20056738].
61 Coffee B, Keith K, Albizua I, et al. Incidence of Fragile X Syndrome by newborn screening for methylated FMR1 DNA. Am J Hum Genet. Oct. 9. 2009;85(4):503-14. [pmid: 19804849].
62 Hu H, Wrogemann K, Kalscheuer V, et al. Mutation screening in 86 known X-linked mental retardation genes by droplet-based multiplex PCR and massive parallel sequencing. Hugo J. Dec. 2009;3(1–4):41-9. [pmid: 21836662].
63 Wang W, Law HY, Chong SS. Detection and discrimination between deletional and non-deletional prader-willi and angelman syndromes by methylation-specific pcr and quantitative melting curve analysis. J Mol Diagn. Sep. 2009;11(5):446-9. [pmid: 19661385].
64 Truong HT, Solaymani-Kohal S, Baker KR, et al. Diagnosing Smith-Magenis syndrome and duplication 17p11.2 syndrome by RAI1 gene copy number variation using quantitative real-time PCR. Genet Test. Mar. 2008;12(1):67-73. [pmid: 18373405].
65 Ballif BC, Sulpizio SG, Lloyd RM, et al. The clinical utility of enhanced subtelomeric coverage in array CGH. Am J Med Genet A. Aug. 15. 2007;143A(16):1850-7. [pmid: 17632771].
66 Shen Y, Irons M, Miller DT, et al. Development of a focused oligonucleotide-array comparative genomic hybridization chip for clinical diagnosis of genomic imbalance. Clin Chem. Dec. 2007;53(12):2051-9. [pmid: 17901113].
67 Altug-Teber O, Dufke A, Poths S, et al. A rapid microarray based whole genome analysis for detection of uniparental disomy. Hum Mutat. Aug. 2005;26(2):153-9. [pmid: 15968682].
68 Lee H, Deignan JL, Dorrani N, et al. Clinical exome sequencing for genetic identification of rare mendelian disorders. JAMA. Nov. 12. 2014;312(18):1880-7. http://dx.doi.org/10.1001/jama.2014.14604. [pmid: 25326637].
69 Yang Y, Muzny DM, Xia F, et al. Molecular findings among patients referred for clinical whole-exome sequencing. JAMA. Nov. 12. 2014;312(18):1870-9. http://dx.doi.org/10.1001/jama.2014.14601. [pmid: 25326635].
70 Pereira RR, Pinto IP, Minasi LB, et al. Screening for intellectual disability using high-resolution CMA technology in a retrospective cohort from central Brazil. PLoS ONE. Jul. 25. 2014;9(7):e103117. http://dx.doi.org/10.1371/journal.pone.0103117. [pmid: 25061755].
71 Tao VQ, Chan KYK, Chu YWY, et al. The clinical impact of chromosomal microarray on paediatric care in Hong Kong. PLoS ONE. Oct. 15. 2014;9(10). http://dx.doi.org/10.1371/journal.pone.0109629.
72 Soden SE, Saunders CJ, Willig LK, et al. Effectiveness of exome and genome sequencing guided by acuity of illness for diagnosis of neurodevelopmental disorders. Sci Transl Med. Dec. 3. 2014;6(265):265ra168. http://dx.doi.org/10.1126/scitranslmed.3010076. [pmid: 25473036].
73 Bartnik M, Nowakowska B, Derwinska K, et al. Application of array comparative genomic hybridization in 256 patients with developmental delay or intellectual disability. J Appl Genet. Feb. 2014;55(1):125-44. [pmid: 24297458].
74 Boggula VR, Shukla A, Danda S, et al. Clinical utility of multiplex ligation-dependent probe amplification technique in identification of aetiology of unexplained mental retardation: A study in 203 indian patients. Ind J Med Res. Jan. 2014:66-75.
75 Byeon JH, Shin E, Kim GH, et al. Application of array-based comparative genomic hybridization to pediatric neurologic diseases. Yonsei Med J. Jan. 2014;55(1):30-6. [pmid: 24339284].
76 Chaudhary AG, Hussein IR, Abuzenadah A, et al. Molecular diagnosis of fragile X syndrome using methylation sensitive techniques in a cohort of patients with intellectual disability. Pediatr Neurol. Apr. 2014;50(4):368-76. [pmid: 24630283].
77 Cheon CK, Sohn YB, Ko JM, et al. Identification of KMT2D and KDM6A mutations by exome sequencing in Korean patients with Kabuki syndrome. J Hum Genet. Jun. 2014;59(6):321-5. [pmid: 24739679].
78 Chong WW, Lo IF, Lam ST, et al. Performance of chromosomal microarray for patients with intellectual disabilities/developmental delay, autism, and multiple congenital anomalies in a Chinese cohort. Mol Cytogenet. May. 23. 2014;7(1):34. [pmid: 24926319].
79 Coutton C, Dieterich K, Satre V, et al. Array-CGH in children with mild intellectual disability: a population-based study. Eur J Pediatr. 2014. Jul. 3. Epub ahead of print. [pmid: 24985125].
80 Dubourg C, Bonnet-Brilhault F, Toutain A, et al. Identification of nine new rai1-truncating mutations in smith-magenis syndrome patients without 17p11.2 deletions. Mol Syndromol. Feb. 2014;5(2):57-64. [pmid: 24715852].
81 Fatima T, Zaidi SA, Sarfraz N, et al. Frequency of FMR1 gene mutation and CGG repeat polymorphism in intellectually disabled children in Pakistan. Am J Med Genet A. May. 2014;164(5):1151-61. [pmid: 24478267].
82 Gilissen C, Hehir-Kwa JY, Thung DT, et al. Genome sequencing identifies major causes of severe intellectual disability. Nature. 2014;511(7509):344-7. [pmid: 24896178].
83 Helsmoortel C, Vandeweyer G, Ordoukhanian P, et al. Challenges and opportunities in the investigation of unexplained intellectual disability using family based whole exome sequencing. Clin Genet. 2014. Aug. 1. Epub ahead of print. [pmid: 25081361].
84 Huguet G, Nava C, Lemiere N, et al. Heterogeneous pattern of selective pressure for PRRT2 in human populations, but no association with autism spectrum disorders. PLoS ONE. 2014;9(3):e88600. [pmid: 24594579].
85 Lee JS, Byun CK, Kim H, et al. Clinical and mutational spectrum in Korean patients with Rubinstein-Taybi syndrome: The spectrum of brain MRI abnormalities. Brain Dev. 2014. Aug. 6. Epub ahead of print. [pmid: 25108505].
86 Medina A, Pineros L, Arteaga C, et al. Multiplex ligation-dependent probe amplification to subtelomeric rearrangements in idiopathic intellectual disability in Colombia. Pediatr Neurol. Mar. 2014;50(3):250-4. [pmid: 24412240].
87 Nicholl J, Waters W, Mulley JC, et al. Cognitive deficit and autism spectrum disorders: prospective diagnosis by array CGH. Pathology (Phila). Jan. 2014;46(1):41-5. [pmid: 24300712].
88 Palmer E, Speirs H, Taylor PJ, et al. Changing interpretation of chromosomal microarray over time in a community cohort with intellectual disability. Am J Med Genet A. Feb. 2014;164A(2):377-85. [pmid: 24311194].
89 Stobbe G, Liu Y, Wu R, et al. Diagnostic yield of array comparative genomic hybridization in adults with autism spectrum disorders. Genet Med. Jan. 2014;16(1):70-7. [pmid: 23765050].
90 Tucker T, Zahir FR, Griffith M, et al. Single exon-resolution targeted chromosomal microarray analysis of known and candidate intellectual disability genes. Eur J Hum Genet. Jun. 2014;22(6):792-800. [pmid: 24253858].
91 Tuysuz B, Kartal N, Erener-Ercan T, et al. Prevalence of prader-willi syndrome among infants with hypotonia. J Pediatr. 2014;164(5):1064-7. [pmid: 24582009].
92 Utine GE, Haliloglu G, Volkan-Salanci B, et al. Etiological yield of SNP microarrays in idiopathic intellectual disability. Eur J Paediatr Neurol. May. 2014;18(3):327-37. Epub 2014 Jan 25. [pmid: 24508361].
93 Uwineza A, Caberg JH, Hitayezu J, et al. Array-CGH analysis in Rwandan patients presenting development delay/intellectual disability with multiple congenital anomalies. BMC Med Genet. 2014;15(1):79. [pmid: 25016475].
94 Vergult S, Van Binsbergen E, Sante T, et al. Mate pair sequencing for the detection of chromosomal aberrations in patients with intellectual disability and congenital malformations. Eur J Hum Genet. May. 2014;22(5):652-9. [pmid: 24105367].
95 Willemsen MH, Kleefstra T. Making headway with genetic diagnostics of intellectual disabilities. Clin Genet. Feb. 2014;85(2):101-10. [pmid: 23895455].
96 Wiszniewska J, Bi W, Shaw C, et al. Combined array CGH plus SNP genome analyses in a single assay for optimized clinical testing. Eur J Hum Genet. Jan. 2014;22(1):79-87. [pmid: 23695279].
97 Ahn JW, Bint S, Bergbaum A, et al. Array CGH as a first line diagnostic test in place of karyotyping for postnatal referrals - results from four years’ clinical application for over 8,700 patients. Mol Cytogenet. 2013;6(1):16. [pmid: 23560982].
98 Battaglia A, Doccini V, Bernardini L, et al. Confirmation of chromosomal microarray as a first-tier clinical diagnostic test for individuals with developmental delay, intellectual disability, autism spectrum disorders and dysmorphic features. Eur J Paediatr Neurol. Nov. 2013;17(6):589-99. [pmid: 23711909].
99 Behjati F, Ghasemi Firouzabadi S, Sajedi F, et al. Identification of chromosome abnormalities in subtelomeric regions using Multiplex Ligation Dependent Probe Amplification (MLPA) Technique in 100 Iranian patients with idiopathic mental retardation. Iran Red Crescent Med J. Oct. 2013;15(10):e8221. [pmid: 24693374].
100 Behjati F, Firouzabadi SG, Kariminejad R, et al. Genomic characterization of some Iranian children with idiopathic mental retardation using array comparative genomic hybridization. Indian J Hum Genet. Oct–Dec. 2013;19(4):443-8. [pmid: 24497710].
101 Del Carmen Montes C, Sturich A, Chaves A, et al. Clinical fndings in 32 patients with 22qll.2 microdeletion attended in the city of Cordoba, Argentina. Arch Argent Pediatr. Oct. 2013;111(5):423-7. [pmid: 24092030].
102 Doherty E, O’Connor R, Zhang A, et al. Developmental delay referrals and the roles of Fragile X testing and molecular karyotyping: a New Zealand perspective. Mol Med Rep. May. 2013;7(5):1710-4. [pmid: 23525284].
103 Esposito G, Ruggiero R, Savarese G, et al. A 15-year case-mix experience for fragile X syndrome molecular diagnosis and comparison between conventional and alternative techniques leading to a novel diagnostic procedure. Clin Chim Acta. Feb. 18. 2013:85-9. [pmid: 23279920].
104 Essop FB, Krause A. Diagnostic, carrier and prenatal genetic testing for fragile X syndrome and other FMR-1-related disorders in Johannesburg, South Africa: A 20-year review. S Afr Med J. 2013;103:994-8. [pmid: 24300646].
105 Fan YS, Ouyang X, Peng J, et al. Frequent detection of parental consanguinity in children with developmental disorders by a combined CGH and SNP microarray. Mol Cytogenet. 2013;6(1):38. [pmid: 24053112].
106 Halder A, Jain M, Chaudhary I, et al. Fluorescence In Situ Hybridization (FISH) using non-commercial probes in the diagnosis of clinically suspected microdeletion syndromes. Ind J Med Res. Aug. 2013;138:135-42.
107 Jain S, Chowdhury V, Juneja M, et al. Intellectual disability in Indian children: Experience with a stratified approach for etiological diagnosis. Indian Pediatr. Dec. 2013;50(12):1125-30. [pmid: 23798638].
108 Jorge P, Oliveira B, Marques I, et al. Development and validation of a multiplex-PCR assay for X-linked intellectual disability. BMC Med Genet. 2013;80. [pmid: 23914978].
109 Kashevarova AA, Skryabin NA, Cheremnykh AD, et al. Clinical and genetic analysis of idiopathic intellectual disability based on array comparative genomic hybridization. Zhurnal Nevrologii i Psihiatrii imeni S.S. Korsakova. 2013;2013(9):70-74.
110 Lee CG, Park SJ, Yun JN, et al. Array-based comparative genomic hybridization in 190 Korean patients with developmental delay and/or intellectual disability: a single tertiary care university center study. Yonsei Med J. 2013;54(6):1463-70. [pmid: 24142652].
111 Marano RM, Mercurio L, Kanter R, et al. Risk assessment models in genetics clinic for array comparative genomic hybridization: clinical information can be used to predict the likelihood of an abnormal result in patients. J Pediat Genet. 2013;2(1):25-31.
112 Mundhofir FE, Nillesen WM, Van Bon BW, et al. Subtelomeric chromosomal rearrangements in a large cohort of unexplained intellectually disabled individuals in Indonesia: A clinical and molecular study. Indian J Hum Genet. Apr. 2013;19(2):171-8. [pmid: 24019618].
113 Nicholl J, Waters W, Suwalski S, et al. Epilepsy with cognitive deficit and autism spectrum disorders: prospective diagnosis by array CGH. Am J Med Genet B Neuropsychiatr Genet. Jan. 2013;162B(1):24-35. Epub 2012 Nov 26. [pmid: 23184456].
114 Pohovski LM, Dumic KK, Odak L, et al. Multiplex ligation-dependent probe amplification workflow for the detection of submicroscopic chromosomal abnormalities in patients with developmental delay/intellectual disability. Mol Cytogenet. 2013;6(1):7. [pmid: 23383958].
115 Pratt DW, Warner JV, Williams MG. Genotyping FOXG1 mutations in patients with clinical evidence of the FOXG1 syndrome. Mol Syndromol. Jan. 2013;3(6):284-7. [pmid: 23599699].
116 Qiao Y, Tyson C, Hrynchak M, et al. Clinical application of 2.7M Cytogenetics array for CNV detection in subjects with idiopathic autism and/or intellectual disability. Clin Genet. Feb. 2013;83(2):145-54. [pmid: 22369279].
117 Rodriguez-Revenga L, Vallespin E, Madrigal I, et al. A parallel study of different array-CGH platforms in a set of Spanish patients with developmental delay and intellectual disability. Gene. May. 25. 2013;521(1):82-6. [pmid: 23524024].
118 Saad K, Abdelrahman AA, Abdallah AM, et al. Clinical and neuropsychiatric status in children with Williams-Beuren Syndrome in Upper Egypt. Asian J Psychiatry. Dec. 2013;6(6):560-5. [pmid: 24309873].
119 Shoukier M, Klein N, Auber B, et al. Array CGH in patients with developmental delay or intellectual disability: are there phenotypic clues to pathogenic copy number variants?. Clin Genet. Jan. 2013;83(1):53-65. [pmid: 22283495].
120 Sorte HS, Gjevik E, Sponheim E, et al. Copy number variation findings among 50 children and adolescents with autism spectrum disorder. Psychiatr Genet. Apr. 2013;23(2):61-9. [pmid: 23277134].
121 Tos T, Vurucu S, Karkucak M, et al. Subtelomeric fish findings in turkish patients with idiopathic mental retardation. Genet Couns. 2013;24(3):259-64. [pmid: 24341139].
122 Vallespin E, Palomares Bralo M, Mori MA, et al. Customized high resolution CGH-array for clinical diagnosis reveals additional genomic imbalances in previous well-defined pathological samples. Am J Med Genet A. Aug. 2013;161A(8):1950-60. [pmid: 23798500].
123 Vallespin E, Palomares Bralo M, Mori MA, et al. Customized high resolution CGH-array for clinical diagnosis reveals additional genomic imbalances in previous well-defined pathological samples. Am J Med Genet A. Aug. 2013;161(8):1950-60. [pmid: 23798500].
124 Vorsanova SG, Iourov IY, Kurinnaya OS, et al. Genomic abnormalities in children with mental retardation and autism: the use of comparative genomic hybridization in situ (HRCGH) and molecular karyotyping with DNA-microchips (array CGH). Zhurnal Nevrologii i Psihiatrii imeni S.S. Korsakova. 2013;2013(8):46-9.
125 Winarni TI, Utari A, Mundhofir FE, et al. Fragile X syndrome: Clinical, cytogenetic and molecular screening among autism spectrum disorder children in indonesia. Clin Genet. Dec. 2013;84(6):577-80. [pmid: 23320543].
126 Zarate YA, Dwivedi A, Bartel FO, et al. Clinical utility of the X-chromosome array. Am J Med Genet A. Jan. 2013;161A(1):120-30. [pmid: 23208842].
127 Aradhya S, Lewis R, Bonaga T, et al. Exon-level array CGH in a large clinical cohort demonstrates increased sensitivity of diagnostic testing for Mendelian disorders. Genet Med. Jun. 2012;14(6):594-603. [pmid: 22382802].
128 Dos Santos SR, Freire-Maia DV. Absence of subtelomeric rearrangements in selected patients with mental retardation as assessed by multiprobe T FISH. J Negat Results Biomed. 2012;11:16. [pmid: 23259705].
129 Hochstenbach R, Poot M, Nijman IJ, et al. Discovery of variants unmasked by hemizygous deletions. Eur J Hum Genet. Jul. 2012;20(7):748-53. [pmid: 22258528].
130 Iourov IY, Vorsanova SG, Kurinnaia OS, et al. Molecular karyotyping by array CGH in a Russian cohort of children with intellectual disability, autism, epilepsy and congenital anomalies. Mol Cytogenet. 2012;5(1):46. [pmid: 23272938].
131 McGrew SG, Peters BR, Crittendon JA, et al. Diagnostic yield of chromosomal microarray analysis in an autism primary care practice: which guidelines to implement?. J Autism Dev Disord. Aug. 2012;42(8):1582-91. [pmid: 22089167].
132 Rafati M, Seyyedaboutorabi E, Ghadirzadeh MR, et al. “Familial” versus “Sporadic” intellectual disability: contribution of common microdeletion and microduplication syndromes. Mol Cytogenet. 2012;5(1):9. [pmid: 22283845].
133 Rafati M, Ghadirzadeh MR, Heshmati Y, et al. “Familial” versus “sporadic” intellectual disability: contribution of subtelomeric rearrangements. Mol Cytogenet. 2012;5(1):4. [pmid: 22260313].
134 Splendore A, da Rocha KM, Takahashi VN, et al. Centro de estudos do genoma humano: Our six-year experience on the molecular diagnosis of rett syndrome. Revista Neurociencias. 2012;20(2):194-9.
135 Tos T, Karaman A, Aksoy A, et al. Structural chromosomal abnormalities in patients with mental retardation and/or multiple congenital anomalies: A new series of 24 patients. Genet Couns. 2012;23(2):289-96. [pmid: 22876589].
136 Tzetis M, Kitsiou-Tzeli S, Frysira H, et al. The clinical utility of molecular karyotyping using high-resolution array-comparative genomic hybridization. Expert Rev Mol Diagn. Jun. 2012;12(5):449-57. [pmid: 22702362].
137 Utine GE, Kiper PO, Alanay Y, et al. Searching for copy number changes in nonsyndromic X-linked intellectual disability. Mol Syndromol. Jan. 2012;2(2):64-71. [pmid: 22511893].
138 Bremer A, Giacobini M, Eriksson M, et al. Copy number variation characteristics in subpopulations of patients with autism spectrum disorders. Am J Med Genet B Neuropsychiatr Genet. Mar. 2011;156(2):115-24. [pmid: 21302340].
139 Bruno DL, White SM, Ganesamoorthy D, et al. Pathogenic aberrations revealed exclusively by single nucleotide polymorphism (SNP) genotyping data in 5000 samples tested by molecular karyotyping. J Med Genet. Dec. 2011;48(12):831-9. [pmid: 22039585].
140 Hannibal MC, Buckingham KJ, Ng SB, et al. Spectrum of MLL2 (ALR) mutations in 110 cases of Kabuki syndrome. Am J Med Genet A. Jul. 2011;155(7):1511-6. [pmid: 21671394].
141 Hayashi S, Imoto I, Aizu Y, et al. Clinical application of array-based comparative genomic hybridization by two-stage screening for 536 patients with mental retardation and multiple congenital anomalies. J Hum Genet. Feb. 2011;56(2):110-24. [pmid: 20981036].
142 Rana KS, Holla RG. To determine the frequency of subtelomeric abnormalities in children with idiopathic mental retardation. Med J Armed Forces India. Oct. 2011;67(4):326-8.
143 Roesser J. Diagnostic yield of genetic testing in children diagnosed with autism spectrum disorders at a regional referral center. Clin Pediatr (Phila). Sep. 2011;50(9):834-43. Epub 2011 Apr 27. [pmid: 21525079].
144 Rooms L, Vandeweyer G, Reyniers E, et al. Array-based MLPA to detect recurrent copy number variations in patients with idiopathic mental retardation. Am J Med Genet A. Feb. 2011;155(2):343-8. [pmid: 21271651].
145 Shawky RM, El-Baz F, Elsobky ES, et al. Screening for subtle chromosomal rearrangements in an Egyptian sample of children with unexplained mental retardation. Egypt J Med Hum Genet. May. 2011;12(1):63-8.
146 Wincent J, Anderlid BM, Lagerberg M, et al. High-resolution molecular karyotyping in patients with developmental delay and/or multiple congenital anomalies in a clinical setting. Clin Genet. Feb. 2011;79(2):147-57. [pmid: 20486943].
147 Dave U, Shetty D. A PCR-based screening method for rapid detection and genetic counseling in Fragile-X syndrome. J Prenatal Diagn Ther. Jan–Jun. 2010;1(1):26-30.
148 Ezugha H, Anderson CE, Marks HG, et al. Microarray analysis in children with developmental disorder or epilepsy. Pediatr Neurol. Dec. 2010;43(6):391-4. [pmid: 21093728].
149 Gervasini C, Mottadelli F, Ciccone R, et al. High frequency of copy number imbalances in Rubinstein-Taybi patients negative to CREBBP mutational analysis. Eur J Hum Genet. Jul. 2010;18(7):768-75. [pmid: 20125191].
150 Manolakos E, Vetro A, Kefalas K, et al. The use of array-CGH in a cohort of Greek children with developmental delay. Mol Cytogenet. 2010;3(1). Article no. 22. [pmid: 21062444].
151 Muscarella LA, Guarnieri V, Sacco R, et al. Candidate gene study of HOXB1 in autism spectrum disorder. Mol Autism. 2010;1:9. [pmid: 20678259].
152 Schaefer GB, Starr L, Pickering D, et al. Array comparative genomic hybridization findings in a cohort referred for an autism evaluation. J Child Neurol. Dec. 2010;25(12):1498-503. [pmid: 20729506].
153 Shen Y, Dies KA, Holm IA, et al. Clinical genetic testing for patients with autism spectrum disorders. Pediatrics. Apr. 2010;125(4):e727-35. [pmid: 20231187].
154 Siggberg L, Ala-Mello S, Jaakkola E, et al. Array CGH in molecular diagnosis of mental retardation - a study of 150 Finnish patients. Am J Med Genet A. Jun. 2010;152A(6):1398-410. [pmid: 20503314].
155 Xiang B, Zhu H, Shen Y, et al. Genome-wide oligonucleotide array comparative genomic hybridization for etiological diagnosis of mental retardation: a multicenter experience of 1499 clinical cases. J Mol Diagn. Mar. 2010;12(2):204-12. [pmid: 20093387].
156 Auber B, Bruemmer V, Zoll B, et al. Identification of subtelomeric genomic imbalances and breakpoint mapping with quantitative PCR in 296 individuals with congenital defects and/or mental retardation. Mol Cytogenet. 2009;2(1):10. [pmid: 19284615].
157 Baris I, Battaloglu E. A multiplexed ARMS-PCR approach for the detection of common MECP2 mutations. Genet Test Mol Biomarkers. Feb. 2009;13(1):19-22. [pmid: 19309269].
158 Bhowmik DA, Dutta S, Chatterjee A, et al. Screening for fragile X syndrome among neurobehavioural patients from Kolkata, Eastern India. J Clin Diagn Res. 2009;3(1):1266-73.
159 Bucan M, Abrahams BS, Wang K, et al. Genome-wide analyses of exonic copy number variants in a family-based study point to novel autism susceptibility genes. PLoS Genet. Jun. 2009;5(6):e1000536. [pmid: 19557195].
160 Cho EH, Park BY, Cho JH, et al. Comparing two diagnostic laboratory tests for several microdeletions causing mental retardation syndromes: multiplex ligation-dependent amplification vs fluorescent in situ hybridization. Korean J Lab Med. Feb. 2009;29(1):71-6. [pmid: 19262082].
161 Cusco I, Medrano A, Gener B, et al. Autism-specific copy number variants further implicate the phosphatidylinositol signaling pathway and the glutamatergic synapse in the etiology of the disorder. Hum Mol Genet. 2009;18(10):1795-804. [pmid: 19246517].
162 Dutta S, Das M, Bhowmik AD, et al. Screening of rural children in west bengal for Fragile-X syndrome. Ind J Med Res. Dec. 2009;130(6):714-9. [pmid: 20090132].
163 Friedman JM, Adam S, Arbour L, et al. Detection of pathogenic copy number variants in children with idiopathic intellectual disability using 500 K SNP array genomic hybridization. BMC Genomics. Nov. 16. 2009;10:526. [pmid: 19917086].
164 Gijsbers AC, Lew JY, Bosch CA, et al. A new diagnostic workflow for patients with mental retardation and/or multiple congenital abnormalities: test arrays first. Eur J Hum Genet. Nov. 2009;17(11):1394-402. [pmid: 19436329].
165 Giorda R, Bonaglia MC, Beri S, et al. Complex segmental duplications mediate a recurrent dup(X)(p11.22–p11.23) Associated with Mental Retardation, Speech Delay, and EEG Anomalies in Males and Females. Am J Hum Genet. Sep. 11. 2009;85(3):394-400. [pmid: 19716111].
166 Hochstenbach R, van Binsbergen E, Engelen J, et al. Array analysis and karyotyping: Workflow consequences based on a retrospective study of 36,325 patients with idiopathic developmental delay in the Netherlands. Eur J Med Genet. Jul–Aug. 2009;52(4):161-9. [pmid: 19362174].
167 Koolen DA, Pfundt R, de Leeuw N, et al. Genomic microarrays in mental retardation: a practical workflow for diagnostic applications. Hum Mutat. Mar. 2009;30(3):283-92. [pmid: 19085936].
168 McMullan DJ, Bonin M, Hehir-Kwa JY, et al. Molecular karyotyping of patients with unexplained mental retardation by SNP arrays: A multicenter study. Hum Mutat. Jul. 2009;30(7):1082-92. [pmid: 19388127].
169 Shahdadpuri R, Lambert D, Lynch SA. Diagnostic outcome following routine genetics clinic referral for the assessment of global developmental delay. Ir Med J. May. 2009;102(5):146-8. [pmid: 19623810].
170 Utine GE, Celik T, Alanay Y, et al. Subtelomeric rearrangements in mental retardation: Hacettepe University experience in 130 patients. Turk J Pediatr. 2009;51(3):199-206. [pmid: 19817261].
171 Mandal K, Boggula VR, Borkar M, et al. Use of multiplex ligation-dependent probe amplification (MLPA) in screening of subtelomeric regions in children with idiopathic mental retardation. Indian J Pediatr. Oct. 2009;76(10):1027-31. [pmid: 19907935].
172 Baris HN, Tan WH, Kimonis VE, et al. Diagnostic utility of array-based comparative genomic hybridization in a clinical setting. Am J Med Genet A. Nov. 1. 2007;143A(21):2523-33. [pmid: 17910064].
173 de Souza DH, Moretti-Ferreira D, de Souza Rugolo LM. Flourescent In Situ Hybridization (FISH) as a diagnostic tool for Williams-Beuren Syndrome. Genet Mol Biol. 2007;30(1):17-20.
174 Newman WG, Hamilton S, Ayres J, et al. Array comparative genomic hybridization for diagnosis of developmental delay: an exploratory cost-consequences analysis. Clin Genet. Mar. 2007;71(3):254-9. [pmid: 17309648].
175 Sandrin-Garcia P, Richieri-Costa A, Tajara EH, et al. Flourescence in situ hybridization (FISH) screening for the 22q11.2 deletion in patients with clinical features of velocardiofacial syndrome but without cardiac anomalies. Genet Mol Biol. 2007;30(1):21-4.
176 van Hagen JM, Eussen HJ, van Schooten R, et al. Comparing two diagnostic laboratory tests for Williams syndrome: fluorescent in situ hybridization versus multiplex ligation-dependent probe amplification. Genet Test. 2007;11(3):321-7. [pmid: 17949295].
177 Coupry I, Monnet L, Attia AA, et al. Analysis of CBP (CREBBP) gene deletions in Rubinstein-Taybi syndrome patients using real-time quantitative PCR. Hum Mutat. Mar. 2004;23(3):278-84. [pmid: 14974086].
178 Kleefstra T, Yntema HG, Nillesen WM, et al. MECP2 analysis in mentally retarded patients: implications for routine DNA diagnostics. Eur J Hum Genet. Jan. 2004;12(1):24-8. [pmid: 14560307].
179 Vermeesch JR, Fiegler H, de Leeuw N, et al. Guidelines for molecular karyotyping in constitutional genetic diagnosis. Eur J Hum Genet. Nov. 2007;15(11):1105-14. [pmid: 17637806].
180 Finsterer J, Harbo HF, Baets J, et al. EFNS guidelines on the molecular diagnosis of mitochondrial disorders. Eur J Neurol. Dec. 2009;16(12):1255-64. [pmid: 19950421].
181 National Institute for Health and Clinical Excellence (NICE). Autism. Recognition, referral and diagnosis of children and young people on the autism spectrum. London (UK). National Institute for Health and Clinical Excellence (NICE). 2011. Sep. 51 p. (Clinical guideline; no.128).
182 Singapore Ministry of Health. Autism spectrum disorders in pre-school children. Singapore. Singapore Ministry of Health. 2010. Mar. 140 p.
183 Kearney HM, South ST, Wolff DJ, et al. American College of Medical Genetics recommendations for the design and performance expectations for clinical genomic copy number microarrays intended for use in the postnatal setting for detection of constitutional abnormalities. Genet Med. Jul. 2011;13(7):676-9. [pmid: 21681105].
184 Ramsden SC, Clayton-Smith J, Birch R, et al. Practice guidelines for the molecular analysis of Prader-Willi and Angelman syndromes. BMC Med Genet. 2010;70. [pmid: 20459762].
185 McConkieRosell A, Abrams L, Finucane B, et al. Recommendations from multi-disciplinary focus groups on cascade testing and genetic counseling for fragile X-associated disorders. J Genet Couns. Oct. 2007;16(5):593-606. [pmid: 17497108].
186 South ST, Lee C, Lamb AN, et al. ACMG Standards and Guidelines for constitutional cytogenomic microarray analysis, including postnatal and prenatal applications: Revision 2013. Genet Med. Nov. 2013;15(11):901-9. http://dx.doi.org/10.1038/gim.2013.129. [pmid: 24071793].
187 Vermeesch JR, Brady PD, Sanlaville D, et al. Genome-wide arrays: quality criteria and platforms to be used in routine diagnostics. Hum Mutat. Jun. 2012;33(6):906-15. http://dx.doi.org/10.1002/humu.22076. [pmid: 22415865].
188 Hanemaaijer NM, Sikkema-Raddatz B, van der Vries G, et al. Practical guidelines for interpreting copy number gains detected by high-resolution array in routine diagnostics. Eur J Hum Genet. Feb. 2012;20(2):161-5. [pmid: 21934709].
189 Neul JL, Kaufmann WE, Glaze DG, et al. Rett syndrome: Revised diagnostic criteria and nomenclature. Ann Neurol. Dec. 2010;68(6):944-50. http://dx.doi.org/10.1002/ana.22124. [pmid: 21154482].
190 Finucane B, Abrams L, Cronister A, et al. Genetic counseling and testing for FMR1 gene mutations: practice guidelines of the National Society of Genetic Counselors. J Genet Couns. Dec. 2012;21(6):752-60. [pmid: 22797890].
191 Hochstenbach R, Buizer-Voskamp JE, Vorstman JA, et al. Genome arrays for the detection of copy number variations in idiopathic mental retardation, idiopathic generalized epilepsy and neuropsychiatric disorders: lessons for diagnostic workflow and research. Cytogenet Genome Res. 2011;135(3–4):174-202. [pmid: 22056632].
192 Sagoo GS, Butterworth AS, Sanderson S, et al. Array CGH in patients with learning disability (mental retardation) and congenital anomalies: Updated systematic review and meta-analysis of 19 studies and 13,926 subjects. Genet Med. Mar. 2009;11(3):139-46. [pmid: 19367186].
193 New NIH-funded resource focuses on use of genomic variants in medical care. Bethesda (MD). National Institutes of Health (NIH). 2013. Sep. 25. http://www.nih.gov/news/health/sep2013/nhgri-25.htm. Accessed 2014 Dec 04.
194 Agency for Healthcare Research and Quality (AHRQ). Methods guide for medical test reviews. [AHRQ Publication No. 12-EHC017]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Jun. 2012:188. http://effectivehealthcare.ahrq.gov/ehc/products/246/558/Methods-Guide-for-Medical-Test-Reviews_Full-Guide_20120530.pdf.
195 Leeflang MM, Deeks JJ, Gatsonis C, et al. Systematic reviews of diagnostic test accuracy. Ann Intern Med. Dec. 16. 2008;149(12):889-97. [pmid: 19075208].