# Methods

We describe below the methods for addressing the guiding questions previously defined.

## Discussions with Key Informants

Within the Technical Brief process, Key Informants (KIs) serve as a resource to offer insight into the clinical context of the technology/intervention, how it works, how it is used or might be used, and which features may be important from a patient standpoint. The input of KIs were particularly important for this Technical Brief, because the area of genetic testing for developmental disabilities (DDs) is complex and published data for addressing some of the guiding questions are unavailable. The KIs helped identify relevant data sources and contributed to a better understanding of how advanced genetic tests work, their role in clinical practice, and potential advantages or harms. The KIs who worked with us for this project include clinicians who treat patients with DD, experts on genetic testing, patient advocates, medical directors from Medicaid programs, and individuals representing professional societies. Discussions with these KIs allowed us to identify important issues from different perspectives. Office of Management and Budget clearance was not required because we limited our standardized questions to no more than nine nongovernment-associated individuals.

After review and approval by the Agency for Healthcare Research and Quality (AHRQ) of the completed Disclosure of Interest forms for proposed KIs, we held interviews with nine selected KIs. The interviews were held with small groups of KIs based on availability and concordance of perspectives. Each interview was summarized in writing. The KIs’ input was considered as we defined the project’s scope of work and prepared the draft report. Information gained from KI interviews is identified as such in the report.

## Gray Literature Search

A main objective of this Technical Brief is providing information on genetic tests clinically available for diagnosing or determining the etiology of DDs (refer to Guiding Questions 1 and 2). As discussed, the majority of these tests are available as LDTs. Identifying all LDTs within the scope of this Technical Brief has been a challenge and required a multi-faceted approach, including a comprehensive search of peer-reviewed and gray literature. Based on our experience in developing an Evidence-based Practice Center horizon scan report on molecular LDTs33 in addition to the KIs’ input, we used gray literature sources, particularly the National Center for Biotechnology Information (NCBI) Genetic Testing Registry (GTR) (www.ncbi.nlm.nih.gov/gtr/), as the primary source for identifying tests of interest.

NCBI is a division of the National Library of Medicine at the National Institutes of Health. The NCBI’s GTR is a comprehensive information source for testing offered worldwide for disorders with a genetic basis.38 Information is voluntarily submitted by test providers. Each test is assigned a stable identifier of the format GTR000000000. The GTR is designed to capture information on each test (e.g., its purpose, target populations, methods, what it measures, analytical validity, clinical validity, clinical utility, ordering information) and laboratory (e.g., location, contact information, certifications, licenses). However, the voluntarily submitted information is not equally complete for all data elements. For example, data on tests’ analytical validity, clinical validity, or clinical utility are often missing. When these data were available, the sources of the data were rarely provided. In contrast, information on the laboratories that offer genetic tests are mostly complete.

According to its Web site (www.ncbi.nlm.nih.gov/gtr/), GTR requires test providers to review their data annually. Laboratory and test records that are one year beyond the last date they were edited will continue to display on the GTR site but are marked as past annual review. Laboratory and test records that are two years beyond the last date they were edited will be removed from GTR’s public site.

We contacted GTR to request data on genetic tests. To fulfill our request, the GTR staff used the variables we provided and delivered the data in a Microsoft Excel file. We identified tests of interest using key terms for DD conditions (including their synonyms), GTR condition identifiers, and common genes known to be related to the conditions.

We also searched two other U.S.-focused online sources—McKesson Diagnostics Exchange and GeneTests.org—to complement and confirm the information collected from GTR. McKesson Diagnostics Exchange (https://app.mckessondex.com) is an online registry of molecular diagnostic tests. GeneTests.org (www.genetests.org) is a medical genetics information resource including a directory of international laboratories offering genetic testing. Both McKesson Diagnostics Exchange and GeneTests.org are proprietary but accessible by the public. Additional gray data sources we searched include GeneReviews^®^ (www.ncbi.nlm.nih.gov/books/NBK1116/), the Association for Molecular Pathology Test Directory (www.amptestdirectory.org/index.cfm), NCBI’s Online Mendelian Inheritance in Man^®^ (OMIM) database (http://omim.org/), and EuroGentest (www.eurogentest.org).

We further searched other gray literature sources, such as government and specialty society Web sites, clinical trial databases, AHRQ’s Healthcare Horizon Scanning System, trade publications, and meeting abstracts to identify data addressing these tests’ analytic validity, clinical validity, and clinical utility (refer to Guiding Question 3). We also searched professional societies’ Web sites to identify health technology assessment reports, clinical guidelines, and consensus statements, and new tests under development (to address Guiding Question 4).

Our search of the gray literature sources—except for the GTR—only identified a small amount of data on genetic tests. These data are less comprehensive and provide less detail than those identified from the GTR. The additional value of incorporating data from other sources to the data we had collected from the GTR was deemed limited. Methods that allow us to link data from different sources also are lacking. As a result, we decided to rely only on the GTR data for this Technical Brief.

## Published Literature Search

We used a variety of databases to search the peer-reviewed literature, particularly for addressing Guiding Questions 3 and 4. We searched Medline and Embase using Embase.com (http://www.elsevier.com/solutions/embase), and PreMedline and the PubMed in-process subset through the National Library of Medicine Web site. We also searched PsycINFO (OVID) and the Cochrane library (including the Central Register of Controlled Trials, the Cochrane Database of Methodology Reviews, the Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effects, the Health Technology Assessment Database, and the U.K. National Health Service Economic Evaluation Database). The National Guideline Clearinghouse (NGC) was searched for relevant clinical practice guidelines. The searches used a combination of controlled vocabulary terms and free-text words and were limited to English language studies published from January 2000 to January 2015. A detailed literature search strategy is provided in Appendix A.

## Literature Review and Data Abstraction

Because of the broad scope of this Technical Brief (multiple DDs, multiple genetic tests, and various measures of test performance—analytic validity, clinical validity, and clinical utility), we screened and reviewed a large body of literature. Given the limited timeframe of this Technical Brief, a complete review of all full-text articles was not feasible. We therefore collected a portion of the data for this report from a review of abstracts. Given the nature of the data collected, this approach was sufficient for most studies. For example, the vast majority of clinical studies were case series that reported diagnostic yield for a given genetic target or the prevalence of a given genetic aberration among specific patient populations. In such instances, key information such as the study design (i.e., case series) and the reported outcome (e.g., diagnostic yield) were identified with confidence at the abstract level. In cases in which abstracts provided insufficient information, or there was reasonable uncertainty regarding the required data, we retrieved and reviewed full-text articles.

We collected data only from studies published in English that met the inclusion criteria specified in the Scope of Work section of this document. Data collection was guided by the criteria specified on data collection forms included in the Technical Brief Protocol submitted to AHRQ for review before we started the study. Data review and abstraction was performed with DistillerSR^®^, a Web-based systematic review software system (Evidence Partners, Inc., Ottawa, Ontario, Canada). Reviews of each abstract or full-text article and data extraction for each study was performed independently by two researchers. Any discrepancies between the two researchers regarding the selection or review of a given study were resolved through discussion or through arbitration led by a third researcher. Redundancies from multiple publications of the same data sets were identified and eliminated by reviewing author affiliations, study design, enrollment criteria, and enrollment dates. In such cases, the most recently published studies of these data were included in our report.