# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Raphael Bernier, Ph.D.
  Associate Professor, Department of Psychiatry & Behavioral Sciences
  University of Washington
  Seattle, WA
- Linda A. Bradley, Ph.D., FACMG
  Women and Infants Hospital Rhode Island/Alpert Medical School
  Brown University
  Providence, RI
- Edwin H. Cook Jr., M.D.
  Department of Psychiatry
  University of Illinois at Chicago
  Chicago, IL
- Karen W. Gripp, M.D.
  Division of Genetics, Department of Pediatrics
  Nemours Children’s Health System
  Wilmington, DE