# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Michele Caggana, Sc.D.
  Wadsworth Center
  New York State Department of Health
  Albany, NY
- Ellen Roy Elias, M.D.
  Children’s Hospital Colorado
  Aurora, CO
- Margaret Daniele Fallin, Ph.D.
  Johns Hopkins School of Public Health
  Baltimore, MD
- Ian Krantz, M.D.
  Perelman School of Medicine
  University of Pennsylvania
  Philadelphia, PA
- Amy Poole-Yaeger, M.D.
  Centene Corp.
  St. Louis, MO
- Cheryl Reid, M.D.
  Horizon Blue Cross Blue Shield of New Jersey
  West Trenton, NJ
- Stuart Shapira, M.D., Ph.D.
  National Center on Birth Defects and Developmental Disabilities
  Centers for Disease Control and Prevention
  Atlanta, GA
- Peter J. Smith, M.D., M.A.
  Associate Professor of Pediatrics
  University of Chicago
  Chicago, IL
- Marc Williams, M.D., FAAP, FACMG
  Genomic Medicine Institute
  Geisinger Health System
  Danville, PA