# Acknowledgments

The authors thank Eileen Erinoff for her assistance in literature search, Janice Kaczmarek and Gina Giradi for their help in coordinating the project, Eloise DeHaan for copyediting, and Lydia Dharia and Kitty Donahue for document formatting and reference management. We also thank Dr. Craig A Umscheid, Senior Associate Director of ECRI–Penn Medicine AHRQ Evidence-based Practice Center (EPC) for recruiting clinical investigators. We would like to thank the Key Informants, Peer Reviewers, Task Order Officer, and Associate Editor, Dr. Margaret A. Piper, of the Kaiser Permanente Research Affiliates Evidence-based Practice Center, for their invaluable input. We would also like to thank the staff of the National Center for Biotechnology Information (NCBI) Genetic Testing Registry (GTR) for providing us with data on genetic tests.