# Findings

The findings of this Technical Brief are organized in the order of the Guiding Questions.

## Genetic Tests for Developmental Disabilities (Guiding Questions 1 and 2)

Our search of the National Center for Biotechnology Information (NCBI) Genetic Testing Registry (GTR) database identified 672 tests (each assigned a unique GTR identifier) within the scope of this Technical Brief. These tests are offered by 63 providers located in 29 states (see Table 1). They are used for diagnosing, screening, or assessing the risk of developmental disabilities (DDs). They are all registered as “clinical tests” with “how to order” information. As we previously discussed, genetic tests are clinically available in the United States either as a FDA-cleared or -approved test or a laboratory-developed test (LDT). All the GTR tests identified are deemed to be LDTs, because the only FDA-cleared genetic test for developmental disorders (discussed later in this section) is not among these GTR tests.

Table 1 Summary of genetic tests: availability

Condition | Number of Tests Identified | Number of Laboratories Offering the Tests | Number of States Where Laboratories Are Located | States Where Laboratories Are Located | Number of Tests Participating in a PT Program
Angelman syndrome | 82 | 39 | 24 | California, Connecticut, Florida, Georgia, Illinois, Indiana, Massachusetts, Michigan, Minnesota, Mississippi, Missouri, Nebraska, New Jersey, New York, North Carolina, Ohio, Oklahoma, Oregon, Pennsylvania, South Carolina, Texas, Utah, Virginia, Wisconsin | 45
Autism spectrum disorders | 93 | 23 | 16 | California, Colorado, Connecticut, Florida, Georgia, Maryland, Massachusetts, Michigan, Nebraska, New York, Ohio, Pennsylvania, Texas, Utah, Virginia, Wisconsin | 31
Fragile X syndrome | 56 | 34 | 20 | California, Colorado, Florida, Georgia, Iowa, Massachusetts, Michigan, Mississippi, Missouri, Montana, Nebraska, New York, Ohio, Oklahoma, Oregon, Pennsylvania, South Carolina, Texas, Utah, Wisconsin | 30
Global developmental delay | 27 | 18 | 13 | California, Connecticut, Florida, Georgia, Illinois, Maryland, Massachusetts, Michigan, New York, Ohio, Texas, Utah, Virginia | 17
Intellectual disability/mental retardation | 333 | 23 | 16 | California, Colorado, Connecticut, Georgia, Illinois, Iowa, Massachusetts, Michigan, Nebraska, Ohio, Oklahoma, Pennsylvania, South Carolina, Texas, Utah, Wisconsin | 114
Prader-Willi syndrome | 50 | 39 | 24 | California, Florida, Georgia, Illinois, Indiana, Iowa, Massachusetts, Michigan, Mississippi, Missouri, Montana, Nebraska, New Jersey, New York, North Carolina, Ohio, Oklahoma, Oregon, Pennsylvania, South Carolina, Texas, Utah, Virginia, Wisconsin | 37
Rett syndrome | 100 | 24 | 18 | California, Connecticut, Delaware, Florida, Georgia, Illinois, Massachusetts, Michigan, Mississippi, Missouri, Nebraska, Oklahoma, Oregon, Pennsylvania, South Carolina, Texas, Utah, Wisconsin | 52
Rubinstein-Taybi syndrome | 23 | 8 | 8 | California, Colorado, Georgia, Illinois, Massachusetts, Nebraska, Ohio, Texas | 5
Smith-Magenis syndrome | 29 | 19 | 12 | California, Connecticut, Georgia, Indiana, Massachusetts, Michigan, Nebraska, Ohio, Texas, Utah, Virginia, Wisconsin | 14
Velocardiofacial syndrome | 44 | 28 | 17 | California, Connecticut, Florida, Georgia, Illinois, Indiana, Maryland, Massachusetts, Michigan, Montana, Nebraska, New York, Ohio, Texas, Utah, Virginia, Wisconsin | 23
Williams syndrome | 22 | 16 | 11 | California, Georgia, Indiana, Massachusetts, Michigan, Nebraska, New York, Ohio, Utah, Virginia, Wisconsin | 15

Source: National Center for Biotechnology Information’s Genetic Testing Registry

PT=proficiency testing

The tables in Appendix D include detailed information about the GTR tests identified. The information is organized by the 11 DD categories, including intellectual disability (ID), autism spectrum disorder (ASD), global developmental delay (GDD), Angelman syndrome, fragile X syndrome, Prader-Willi syndrome, Rett syndrome, Rubinstein-Taybi syndrome, Smith-Magenis syndrome, velocardiofacial syndrome, and Williams syndrome. Some tests are used for more than one DD category (e.g., used for both ID and fragile X syndrome or for both ASD and Rett syndrome). In these cases, the tests are counted in all categories that apply. These tables include the following information for each test:

- GTR test identification number
- Test provider information (name, location, lab test identification number, CLIA number)
- Target chromosomal regions or genes
- Genetic method used for analysis
- Specimen source
- Whether pre- or post-test counseling is required
- Whether the test is included in any proficiency testing program

All the data identified from the GTR were voluntarily reported by laboratories. NCBI established its protocol to guide the data submission process.38 GTR provides the following note on its Web site (www.ncbi.nlm.nih.gov/gtr/):

NIH [National Institutes of Health] does not independently verify information submitted to the GTR; it relies on submitters to provide information that is accurate and not misleading. NIH makes no endorsements of tests or laboratories listed in the GTR. GTR is not a substitute for medical advice. Patients and consumers with specific questions about a genetic test should contact a health care provider or a genetics professional.

We did not independently verify the data’s accuracy either. Readers should use caution when they interpret data from GTR.

In addition, we identified some GTR tests listed under certain DD categories that analyze a gene without an established association with the DDs. For example, some tests listed under the velocardiofacial syndrome category analyze the FBN1 gene. This gene does not have an established association with velocardiofacial syndrome. FBN1 testing is typically used for diagnosing Marfan syndrome. Laboratories registered these tests under the velocardiofacial syndrome category most likely for the purpose of differential diagnosis. For this Technical Brief, we excluded FBN1 tests from the velocardiofacial syndrome category. We also excluded tests of the same nature from other DD categories.

Table 1, Table 2, and Table 3 are a summary of the genetic tests we identified from the GTR database. As Table 1 indicates, we identified more tests for ID (or mental retardation) than for any other DD category. Not every State has a laboratory that offers genetic tests for DDs. The impact of the laboratories’ geographic distribution on genetic tests’ availability is unclear, because patients may receive testing services from laboratories in other States. Some laboratories offer multiple tests for the same DDs (e.g., ID, ASD). These tests differ in gene markers targeted and analysis methods used.

Table 2 Summary of genetic tests: commonly used methods

Condition | CGH | Microarray | SNP Detection | NGS/MPS | Sanger Sequence Analysis | MLPA | PCR | FISH | Southern Blot | Methylation Analysis | Trinucleotide Repeats Analysis
Angelman syndrome | 6 | 3 | 1 | 24 | 27 | 9 | 20 | 8 | 2 | 14 | 2
Autism spectrum disorders | 11 | 16 | 7 | 29 | 30 | 9 | 6 | 1 | 4 | 0 | 4
Fragile X syndrome | 3 | 3 | 0 | 7 | 5 | 0 | 42 | 0 | 34 | 5 | 33
Global developmental delay | 1 | 13 | 7 | 7 | 2 | 0 | 1 | 0 | 0 | 0 | 0
Intellectual disability/mental retardation | 83 | 35 | 2 | 122 | 141 | 22 | 4 | 0 | 2 | 0 | 2
Prader-Willi syndrome | 0 | 2 | 1 | 5 | 1 | 6 | 28 | 10 | 4 | 24 | 3
Rett syndrome | 7 | 3 | 0 | 37 | 43 | 28 | 5 | 1 | 2 | 1 | 2
Rubinstein-Taybi syndrome | 2 | 3 | 0 | 6 | 10 | 5 | 0 | 0 | 0 | 0 | 0
Smith-Magenis syndrome | 2 | 3 | 0 | 12 | 5 | 0 | 0 | 6 | 0 | 0 | 0
Velocardiofacial syndrome | 4 | 3 | 0 | 20 | 3 | 0 | 1 | 8 | 0 | 0 | 0
Williams syndrome | 0 | 1 | 0 | 6 | 0 | 0 | 0 | 8 | 0 | 0 | 0

Source: National Center for Biotechnology Information’s Genetic Testing Registry

Note: Some tests use more than one method.

CGH=comparative genomic hybridization; FISH=fluorescence in situ hybridization; MLPA=multiplex ligation-dependent probe amplification; NGS/MPS=next-generation sequencing/massively parallel sequencing; PCR=polymerase chain reaction; SNP=single nucleotide polymorphism

Table 3 Summary of genetic tests: genetic targets

Condition | Numbers of Single-Gene Tests | Common Target of Single-Gene Tests (Number of Tests) | Numbers of Tests Analyzing Multiple Genes | Numbers of Tests Analyzing a Chromosomal Region or the Whole Genome or Exome
Angelman syndrome | 32 | UBE3A (26), MECP2 (6) | 30 | 19
Autism spectrum disorders | 43 | PTEN (13), MECP2 (7), FMR1 (3) | 32 | 15
Fragile X syndrome | 46 | FMR1 (46) | 8 | 2
Global developmental delay | 4 | CTNND2 (1), FGFR3 (1), FMR1 (1), GFER (1) | 8 | 15
Intellectual disability/mental retardation | 215 | MEF2C (27), ARX (12), CASK (8), HSD17B10 (8), FKRP (6), OPHN1 (6) | 116 | 2
Prader-Willi syndrome | 24 | SNRPN (22), PWARSN (1), MAGEL2 (1) | 5 | 21
Rett syndrome | 59 | MEF2C (41), FOXG1 (18), | 39 | 1
Rubinstein-Taybi syndrome | 17 | CREBBP (12), EP300 (5) | 6 | 1
Smith-Magenis syndrome | 7 | RAI1 (7) | 12 | 10
Velocardiofacial syndrome | 5 | TBX1 (3), HIRA (2) | 20 | 18
Williams syndrome | 1 | ELN (1) | 6 | 15

Source: National Center for Biotechnology Information’s Genetic Testing Registry

Proficiency testing (PT, a program in which externally validated samples are sent to a laboratory to test its accuracy in performing testing using its usual methodology) is performed for only a portion of the tests identified. The percentage of the tests for which proficiency testing is performed varies across the 11 DD categories, ranging from 22 percent for Rubinstein-Taybi syndrome to 74 percent for Prader-Willi syndrome. These PT programs include formal programs (e.g., those sponsored by the American College of Medical Genetics and Genomics and the College of American Pathologists) and intra-laboratory sample exchange programs.

As summarized in Table 2, the common analysis methods used in these tests include comparative genomic hybridization (CGH), microarray, single nucleotide polymorphism (SNP) detection, next-generation sequencing (NGS), bidirectional or unidirectional Sanger sequence analysis, multiplex ligation-dependent probe amplification (MLPA) or other polymerase chain reaction (PCR)-based methods, Southern blot, and fluorescent in situ hybridization (FISH). Some tests use more than one method (e.g., using both microarray and NGS; see tables in Appendix D). Sequencing (including both NGS and Sanger analysis) are the most frequently used methods among the tests identified. In these data tables, we use the same terminology that the GTR uses to label genetic methods. Some of these methods (e.g., microarray and CGH) potentially overlap.

Table 3 summarizes the genetic targets analyzed by the tests identified. GTR reports these target as a single gene (e.g., PTEN, FMR1, UBE3A, MECP2), a chromosome (e.g., chromosome 15), a chromosomal region (e.g., 15q11-q13), or the whole genome or exome (labelled as “human genome” in the GTR database). The most common targets in single-gene tests vary across DD categories (see Table 3). For the genes included in the multiple-gene tests, see tables in Appendix D.

In the tables in Appendix D, we reported information submitted to the GTR by test providers as to whether genetic counseling is required before or after genetic testing. We did not identify any information addressing credentials required for interpreting test results or data profiling providers who have ordered and used the tests.

Our search of the GRT database identified a limited amount of data on analytic validity or clinical validity for a portion of the 672 tests. However, references were rarely provided for determining where these data came from. We deemed these data to be unreliable and did not report them in this Technical Brief.

In addition to the tests we identified from GTR, we identified one U.S. Food and Drug Administration (FDA)-cleared commercial test kit that met the inclusion criteria for this Technical Brief. On January 17, 2014, the agency cleared Affymetrix CytoScan Dx Assay (Affymetrix, Inc., Santa Clara, CA) for marketing in the United States.39 The test’s FDA-cleared indication is below:39

CytoScan Dx Assay is a qualitative assay intended for the postnatal detection of copy number variations (CNV) in genomic DNA obtained from peripheral whole blood in patients referred for chromosomal testing based on clinical presentation. CytoScan Dx Assay is intended for the detection of CNVs associated with developmental delay, intellectual disability, congenital anomalies, or dysmorphic features. Assay results are intended to be used in conjunction with other clinical and diagnostic findings, consistent with professional standards of practice, including confirmation by alternative methods, parental evaluation, clinical genetic evaluation, and counseling, as appropriate. Interpretation of assay results is intended to be performed only by healthcare professionals, board certified in clinical cytogenetics or molecular genetics. The assay is intended to be used on the GeneChip System 3000Dx and analyzed by Chromosome Analysis Suite Dx Software (ChAS Dx Software).

This device is not intended to be used for standalone diagnostic purposes, preimplantation or prenatal testing or screening, population screening, or for the detection of, or screening for, acquired or somatic genetic aberrations.

According to the 510(k) clearance summary document filed with FDA, Affymetrix CytoScan Dx Assay uses chromosomal microarray technology and provides genome-wide coverage for detecting chromosomal imbalances.39 The CytoScan Dx array contains 2.7 million markers that are representative of DNA sequences distributed throughout the genome. The majority of the markers (1.9 million) are nonpolymorphic markers. The assay reports the copy number state (loss, gain), copy number (i.e., 0, 1, 2, 3, or 4 or greater), and position or location of chromosomal segment copy-number changes across the queried genome.

Affymetrix had submitted data on CytoScan Dx Assay’s performance to FDA for review. The submitted data addressed analytical performance (assay accuracy, precision/reproducibility, stability, assay controls, detection limit, analytical specificity, assay cut-off) and clinical sensitivity and specificity. These data were summarized in the FDA’s 510(k) clearance summary document.39

## Evidence for Addressing Clinical Utility (Guiding Question 3)

Figure 1 summarizes the literature review workflow identifying current evidence for addressing clinical utility. Our search of peer-reviewed journals and gray literature (including manual search of journal articles’ reference lists) identified 2,242 records potentially relevant to the topic of this Technical Brief. We excluded 1,808 articles based on abstract review. Most of the articles were excluded because they were not about a clinical disorder or a genetic test of interest. We were able to extract data from 307 articles at the abstract level. We retrieved 127 full-length articles because their abstracts did not provide sufficient information for data extraction or for judging whether the articles were within the scope of work. We excluded 8 articles at the full-length article level. Then, we extracted data from 119 remaining full-length articles.

Figure 1 Literature review workflow

Figure 1: This figure summarizes the literature review workflow identifying current evidence for addressing clinical utility. Our search of peer-reviewed journals and gray literature identified 2,242 records potentially relevant to the topic of this Technical Brief. We excluded 1,808 articles based on abstract review. Most of the articles were excluded because they are not about a clinical disorder or a genetic tests of interest. We were able to extract data from 307 articles at the abstract level. We retrieved 127 full-length articles. We excluded 8 articles at the full-length article level. Then, we extracted data from 119 remaining full-length articles. Ultimately, we extracted data from 426 studies at either the abstract or full-length article level.

Ultimately, we extracted data from 426 studies at either the abstract or full-length article level. These data include the studies’ design, reported outcomes, sample size, the performance aspects it addressed (e.g., analytic validity, clinical validity, clinical utility), targeted DDs (e.g., ASD, ID, fragile X syndrome), and testing methods used (e.g., PCR, sequencing). These data were exported from the Distiller system into an Excel file for analysis.

Table 4 to Table 9 together provide a map of evidence that directly or indirectly addresses the clinical utility of genetic tests for DDs. for this Technical Brief, we first searched for studies that directly addressed the clinical utility issues. The studies are summarized in Table 4. Our search did not identify any randomized controlled trials (RCTs) or non-RCT studies that directly evaluated the impact of genetic testing on health outcomes. Our search identified seven studies that evaluated the impact of testing on clinical management (e.g., medical referrals, decisions on diagnostic imaging or other laboratory testing, improvement in acquiring services) or family decisions (e.g., reproductive decisions).22,23,40–44 We also identified three studies that evaluated the value of genetic testing perceived by families affected by DDs.25,44,45 These studies do not provide firm evidence regarding the influence of genetic testing on health outcomes, but they help estimate the possibility of an effect. Most identified studies evaluated chromosomal microarray analysis (CMA). Table 5 is a summary of the clinical utility studies organized by DD conditions. Many of these studies addressed genetic testing for multiple conditions. Developmental delay and ID were the most studied conditions.

Table 4 Evidence map: clinical utility studies

Reference | DD Disorder | Test Studied | Study Design | Reported Outcomes | Sample Size
Srivastava et al. 2014^47^ | ASD, DD, ID | Whole exome sequencing | Case series | Changes in clinical management | 78
Amiet 2014^45^ | ASD | CMA and FISH | Survey | Interest in the use of a genetic screening test for ASD | 631
Ellison 2012^40^ | DD, ID, Angelman syndrome, Smith-Magenis syndrome, velocardiofacial syndrome, Williams syndrome | CMA | Case series | Changes in clinical management | 122 (a subset of 46,298 cases)
Iglesias 2014^41^ | DD, ID, ASD | Whole-exome sequencing | Case series | Changes in clinical or family decisions | 115
Costain 2012^44^ | Velocardiofacial syndrome | Molecular diagnosis | Survey | Impact on disease understanding and certainty, on advocacy, and on opportunities to optimize medical, social and educational needs | 118
Mroch 2012^22^ | DD, Rett syndrome | CMA | Case series | Changes in clinical management | 3
Coulter 2011^23^ | DD, ID, ASD | CMA | Case series | Changes in medical care by precipitating medical referrals, diagnostic imaging, or specific laboratory testing | 1,792
Bruno 2009^42^ | ID | CMA | Case series | Changes in clinical or family decisions | 117
Makela 2009^43^ | ID | CMA | Survey | Impact on experiences acquiring services, use of support groups, the family’s reproductive decisions Interest regarding the importance of an etiological diagnosis | 20
Saam 2008^25^ | DD, Prader-Willi syndrome, muscular dystrophy | CMA | Survey | The willingness to pay for diagnostic testing to find a genetic cause of DD from families of children with DD | 48

ASD=autism spectrum disorder; CMA=chromosomal microarray analysis; DD=developmental delay; FISH=fluorescence in situ hybridization; ID=intellectual disability

Table 5 Clinical utility studies by developmental disorders

DD Disorder | Number of Studies | Reference
Angelman syndrome | 1 | Ellison 2012^40^
Autism spectrum disorder | 4 | Amiet 2014^45^, Srivastava et al. 2014^47^, Iglesias 2014^41^, Coulter 2011^23^
Developmental delay | 6 | Srivastava et al. 2014^47^, Iglesias 2014^41^, Ellison 2012^40^, Mroch 2012^22^, Coulter 2011^23^, Saam 2008^25^
Intellectual disability | 6 | Iglesias 2014^41^, Srivastava et al. 2014^47^, Ellison 2012^40^, Coulter 2011^23^, Bruno 2009^42^, Makela 2009^43^
Prader-Willi syndrome | 1 | Saam 2008^25^
Rett syndrome | 1 | Mroch 2012^22^
Smith-Magenis syndrome | 1 | Ellison 2012^40^
Velocardiofacial syndrome | 1 | Ellison 2012^40^ Costain 2012^44^
Williams syndrome | 1 | Ellison 2012^40^

Table 6 Evidence map: analytic validity studies

Reference | DD Disorder | Analysis Methods Used in the Test Studied | Study Design | Reported Outcomes | Sample Size
Kalman 2014^48^ | Rett syndrome | CMA, Sanger sequencing, PCR | Case series | Repeatability/precision | 35
Inaba 2014^49^ | Fragile X syndrome | PCR, methylation analysis | Case-control study | Sensitivity/specificity, Positive/negative predictive value | 685
Hayes 2013^50^ | Developmental delay | CMA, next-generation sequencing, FISH | Cohort study | Sensitivity/specificity | 39
Stofanko 2013^51^ | ID, Smith-Magenis syndrome | Quantitative fluorescent PCR | Case-control study | Sensitivity/specificity, positive/negative predictive value | 428
Stofanko 2013^52^ | ID, ASD, Angelman syndrome, Rett syndrome, velocardiofacial syndrome, Williams syndrome | Quantitative fluorescent PCR | Case-control study | Sensitivity/specificity, Positive/negative predictive value | 29
Koshimizu 2013^53^ | ASD | Next-generation sequencing | Case-control study, case series | Sensitivity/specificity | 38
Lafauci 2013^54^ | Fragile X syndrome | Luminex immunoassay | Case-control study | Sensitivity/specificity, ROC (AUC), repeatability/precision, reference range | 215
Curtis-Cioffi 2012^55^ | Fragile X syndrome | PCR-based screening, Southern blot | Cohort study | Sensitivity/specificity | 78
Juusola 2012^56^ | Fragile X syndrome | PCR-based detection | Case-control study | Sensitivity/specificity, repeatability/precision | 76
Lessard 2012^57^ | Fragile X syndrome | Western blot | Case-control study | Sensitivity/specificity, ROC (AUC), repeatability/precision | 150
Bernardini 2010^58^ | Developmental delay, ID, congenital abnormalities | CMA | Case-control study, case series | Sensitivity/specificity | 70
Chen 2010^59^ | Fragile X syndrome | Single-tube CGG repeat primed FMR1 PCR | Case series | Sensitivity | 227
Filipovic-Sadic 2010^60^ | Fragile X syndrome | FMR1 gene-specific PCR, Southern blot | Case-control study | Sensitivity/specificity, concordance | 146
Coffee 2009^61^ | Fragile X syndrome | Quantitative methylation-sensitive PCR, Southern blot | Case-control study | Sensitivity/specificity, positive/negative predictive value | 36,124
Hu 2009^62^ | Fragile X syndrome | Next-generation sequencing, PCR | Case series | Sensitivity | 24
Wang 2009^63^ | Angelman syndrome, Prader-Willi syndrome | PCR and quantitative melting curve analysis | Case-control study | Ability to discriminate between deletional and nondeletional Prader-Willi and Angelman syndromes | 143
Truong 2008^64^ | Smith-Magenis syndrome | Real-time, quantitative PCR | Case-control study | Repeatability/precision, reported range | 64
Ballif 2007^65^ | Developmental delay, congenital abnormalities | CMA | Case series | Repeatability/precision | 6,946
Shen 2007^66^ | Developmental Delay, ID, ASD, Angelman syndrome, Smith-Magenis syndrome, velocardiofacial syndrome, Williams syndrome | CMA | Case-control study | Sensitivity/specificity, repeatability/precision, concordance, signal-to-noise ratio | 316
Altug-Teber 2005^67^ | Angelman syndrome, Prader-Willi syndrome | CMA | Case series | Sensitivity | 6

ASD=autism spectrum disorder; CMA=chromosomal microarray analysis; FISH=fluorescence in situ hybridization; ID=intellectual disability; PCR=polymerase chain reaction; ROC (AUC)=receiver operator characteristic (area under the curve)

Table 7 Analytic validity studies by developmental disorders

DD Disorder | Number of Studies | Reference
Angelman syndrome | 4 | Stofanko 2013^52^, Wang 2009^63^, Shen 2007^66^, Altug-Teber 2005^67^
Autism spectrum disorder | 3 | Koshimizu 2013^53^, Stofanko 2013^52^, Shen 2007^66^
Developmental delay | 4 | Hayes 2013^50^, Bernardini, 2010^58^, Ballif 2007^65^, Shen 2007^66^
Fragile X syndrome | 9 | Inaba 2014^49^, Lafauci 2013^54^, Curtis-Cioffi 2012^55^, Juusola 2012^56^, Lessard 2012^57^, Chen 2010^59^, Filipovic-Sadic 2010^60^, Coffee 2009^61^, Hu 2009^62^
Intellectual Disability | 4 | Stofanko 2013^51^, Bernardini 2010^58^, Shen 2007^66^, Stofanko 2013^52^
Prader-Willi syndrome | 2 | Wang 2009^63^, Altug-Teber 2005^67^
Rett syndrome | 2 | Kalman 2014^48^, Stofanko 2013^52^
Smith-Magenis syndrome | 3 | Stofanko 2013^51^, Truong 2008^64^, Shen 2007^66^
Velocardiofacial syndrome | 2 | Stofanko 2013^52^, Shen 2007^66^
Williams syndrome | 2 | Stofanko 2013^52^, Shen 2007^66^

Table 8 Case series reporting diagnostic yield

Reference | DD Disorder | Test Studied | Sample Size
Lee et al. 2014^68^ | DD | Whole exome sequencing | 138
Yang et al. 2014^69^ | ASD, DD, ID | Whole exome sequencing | 2,000
Pereira et al. 2014^70^ | ID | CMA | 15
Tao et al. 2014^71^ | ASD, DD, ID | CMA | 327
Soden et al 2014^72^ | ASD, DD, ID and other neurodevelopmental disorders | Whole genome or exome sequencing | 119
Srivastava et al. 2014^47^ | ASD, DD, ID | Whole exome sequencing | 78
Bartnik et al. 2014^73^ | DD, ID, dysmorphic features; congenital anomalies | CMA | 256
Boggula et al. 2014^74^ | DD, ID, PW, SMS, VS, WS | FISH, MLPA | 203
Byeon et al. 2014^75^ | DD, ID | CMA, FISH, standard karyotyping | 87
Chaudhary et al. 2014^76^ | ID, FX | PCR (amplifying methylated CpG dinucleotide region or the unmethylated CGG repeats), Southern blot | 63
Cheon et al. 2014^77^ | ID, Kabuki syndrome | Whole exome and direct sequencing | 12
Chong et al. 2014^78^ | DD, ID, ASD | CMA | 105
Coutton et al. 2014^79^ | ID | CMA | 66
Dubourg et al. 2014^80^ | SMS | PCR, sequencing | 9
Fatima et al. 2014^81^ | ID, FX | PCR (using primers corresponding to modified methylated and unmethylated DNA), Southern blot | 583
Gilissen et al. 2014^82^ | ID | Whole-genome sequencing | 50
Helsmoortel et al. 2014^83^ | ID | CMA, whole-exome sequencing | 10
Huguet et al. 2014^84^ | ASD | Direct sequencing | 1,578
Iglesias et al. 2014^41^ | DD, ID, ASD | Whole exome sequencing | 115
Kalman et al. 2014^48^ | Rett | CMA, Sanger sequencing, semiquantitative PCR | 35
Lee et al. 2014^85^ | RTS | Sequencing, MLPA | 16
Medina et al. 2014^86^ | ID | MLPA | 119
Nicholl et al. 2014^87^ | DD, ID, ASD | CMA | 1,700
Palmer et al. 2014^88^ | ID | CMA | 67
Pereira et al. 2014^70^ | DD, ID | CMA | 305
Stobbe et al. 2014^89^ | ASD | CMA | 36
Tucker et al. 2014^90^ | ID | CMA | 185
Tuysuz et al. 2014^91^ | PW, hypotonia | FISH, methylation analysis; karyotyping | 65
Utine et al. 2014^92^ | ID | CMA | 200
Uwineza et al. 2014^93^ | DD, ID | CMA | 50
Vergult et al. 2014^94^ | ID, congenital malformations | CMA, FISH, mate-pair next-generation sequencing | 50
Willemsen and Kleefstra 2014^95^ | ID | Sanger sequencing | 253
Wiszniewska et al. 2014^96^ | DD, ID | CMA | 3,240
Ahn et al. 2013^97^ | AS, PW, SMS, VS | CMA | 13,412
Battaglia et al. 2013^98^ | DD, ID, ASD | CMA | 349
Behjati et al. 2013^99^ | ID | MLPA | 100
Behjati et al. 2013^100^ | ID | CMA, MLPA | 32
Del Carmen et al. 2013^101^ | VS | FISH | 268
Doherty et al. 2013^102^ | DD, FX | CMA, PCR, Southern blot | 2,046
Esposito et al. 2013^103^ | DD, ID, ASD, FX, facial dysmorphism | PCR, Southern blot | 2,750
Essop and Krause 2013^104^ | ID, FX | PCR, Southern blot | 2,690
Fan et al. 2013^105^ | DD, ASD | CMA | 607
Halder et al. 2013^106^ | AS, PW, VS | FISH | 301
Hayes et al. 2013^50^ | DD, learning difficulties | CMA, FISH, next-generation sequencing | 39
Jain et al. 2013^107^ | ID | CMA, karyotyping, molecular studies for FX | 101
Jorge et al. 2013^108^ | ID, FX | Multiplex PCR | 100
Kashevarova et al. 2013^109^ | DD, ID | CMA | 71
Koshimizu et al. 2013^53^ | ASD | Next-generation sequencing | 38
Lee et al. 2013^110^ | DD, ID | CMA | 190
Marano et al. 2013^111^ | DD, ID, ASD, seizures; dysmorphic features; hypotonia; failure to thrive | CMA | 200
Mundhofir et al. 2013^112^ | ID | MLPA | 436
Nicholl et al. 2013^113^ | DD, ID, ASD, congenital anomalies; epilepsy | CMA | 247
Pohovski et al. 2013^114^ | DD, ID | MLPA | 150
Pratt et al. 2013^115^ | Rett | PCR, Sanger sequencing, MLPA | 12
Qiao et al. 2013^116^ | DD, ID, ASD | CMA, quantitative multiplex PCR | 82
Rodriguez-Revenga et al. 2013^117^ | DD, ID | CMA, FISH, MLPA, quantitative PCR | 200
Saad et al. 2013^118^ | WS | FISH | 17
Shoukier et al. 2013^119^ | DD, ID, congenital anomalies | CMA | 342
Sorte et al. 2013^120^ | ASD | CMA | 50
Tos et al. 2013^121^ | ID | FISH | 67
Vallespin et al. 2013^122^ | DD, ID, ASD | Custom whole-genome oligonucleotide-based array (called KaryoArrayv3.0; Agilent-based 8 × 60 K) | 780
Vallespin et al. 2013^123^ | ID, ASD, multiple congenital anomalies | FISH, custom whole-genome oligonucleotide-based array; MLPA; karyotype | 120
Vorsanova et al. 2013^124^ | ID, ASD | CMA | 100
Winarni et al. 2013^125^ | ASD, FX | PCR, Southern blot, cytogenetic analysis | 65
Zarate et al. 2013^126^ | DD, ID, ASD, FX | CMA, FISH, quantitative PCR | 59
Aradhya et al. 2012^127^ | Mendelian disorders overall | CMA, DNA sequencing | 3,018
Dos Santos and Freire-Maia 2012^128^ | DD, ID | FISH | 15
Ellison et al. 2012^40^ | DD, ID, AS, PW, SMS, VS, WS | CMA | 46,298
Hochstenbach et al. 2012^129^ | ID | Multiplex enrichment and next-generation sequencing of the entire coding sequence of all genes | 20
Iourov et al. 2012^130^ | DD, ID, ASD | CMA | 54
McGrew et al. 2012^131^ | ASD, FX | CMA, fragile X DNA testing | 259
Rafati et al. 2012^132^ | ID | MLPA | 328
Rafati et al. 2012^133^ | ID | FISH, MLPA | 322
Splendore et al. 2012^134^ | Rett | Direct sequencing | 139
Tos et al. 2012^135^ | ID, multiple congenital anomalies | FISH, standard chromosomal analysis | 24
Tzetis et al. 2012^136^ | DD, ID, ASD, deafness, seizures, multiple congenital anomalies | CMA, FISH, “conventional karyotype” | 334
Utine et al. 2012^137^ | ID | MLPA | 100
Bremer et al. 2011^138^ | ASD | CMA | 223
Bruno et al. 2011^139^ | DD, ID, ASD, congenital anomalies | CMA | 5,000
Coulter et al. 2011^23^ | DD, ID, ASD, congenital anomalies | CMA | 1,792
Hannibal et al. 2011^140^ | ID | Sequencing | 110
Hayashi et al. 2011^141^ | ID, multiple congenital anomalies | CMA, conventional cytogenetics | 536
Rana et al. 2011^142^ | ID | MLPA technique for subtelomeric anomalies | 35
Roesser 2011^143^ | ASD | Karyotype, DNA for FX | 507
Rooms et al. 2011^144^ | ID, FX, “negative for FX” | Array-based MLPA | 413
Shawky et al. 2011^145^ | ID | FISH, routine conventional karyotyping, high resolution banding | 30
Wincent et al. 2011^146^ | DD | CMA | 160
Bernardini et al. 2010^58^ | DD, ID, congenital anomalies | CMA | 70
Dave et al. 2010^147^ | ID, FX | PCR, Southern Blot | 720
Ezugha et al. 2010^148^ | DD, ID, ASD, learning disability, hypotonia | CMA | 82
Filipovic-Sadic et al. 2010^60^ | FX | FMR1 gene-specific PCR, Southern blot | 146
Gervasini et al. 2010^149^ | DD, RTS | CMA | 26
Manolakos et al. 2010^150^ | DD, ID | CMA | 82
Muscarella et al. 2010^151^ | ASD | Sanger sequencing, biochemical assay | 862
Schaefer et al. 2010^152^ | ASD | CMA | 89
Shen et al. 2010^153^ | ASD | CMA | 933
Siggberg et al. 2010^154^ | ID | CMA | 150
Xiang et al. 2010^155^ | ID | CMA | 1,499
Auber et al. 2009^156^ | DD, ID | Quantitative PCR | 296
Baris and Battaloglu 2009^157^ | Rett | Multiplex amplification refractory mutation system-PCR | 14
Bhowmik et al. 2009^158^ | FX | Methylation sensitive-PCR, biochemical assay | 157
Bruno et al. 2009^42^ | ID | CMA | 117
Bucan et al. 2009^159^ | ASD | CMA | 4,310
Cho et al. 2009^160^ | ID, AS, PW, VS, WS | FISH, MLPA | 12
Coffee et al. 2009^61^ | FX | Real-time, methylation-sensitive PCR, Southern blot | 36,124
Cusco et al. 2009^161^ | ASD | CMA | 96
Dutta et al. 2009^162^ | DD, ID, FX, congenital malformations | PCR, methylation analysis, cytogenetic analysis | 179
Friedman et al. 2009^163^ | ID | CMA | 300
Gijsbers et al. 2009^164^ | ID, multiple congenital anomalies | CMA | 318
Giorda et al. 2009^165^ | ID | CMA | 2,400
Hochstenbach et al. 2009^166^ | DD, ID | CMA | 36,325
Hu et al. 2009^62^ | FX | Next-generation sequencing, multiplex PCR | 24
Koolen et al. 2009^167^ | ID | CMA | 1,364
McMullan et al. 2009^168^ | ID | CMA | 120
Shahdadpuri et al. 2009^169^ | DD | Targeted DNA testing depending on presentation, often subtelomeric chromosome analysis | 119
Utine et al. 2009^170^ | ID | FISH | 130
Mandal et al. 2009^171^ | ID | MLPA | 65
Truong et al. 2008^64^ | SMS | Real-time, quantitative PCR, MLPA, FISH | 64
Ballif et al. 2007^65^ | DD, congenital anomalies | CMA | 6,946
Baris et al. 2007^172^ | DD, ID, facial dysmorphism, other congenital anomalies | CMA | 373
de Souza et al. 2007^173^ | DD, ID, WS | FISH | 18
Newman et al. 2007^174^ | DD | CMA | 46
Sandrin-Garcia et al. 2007^175^ | VS | FISH | 16
Shen et al. 2007^66^ | DD, ID, ASD, AS, PW, VS, WS | CMA | 316
van Hagen et al. 2007^176^ | WS | FISH, MLPA | 63
Rauch et al. 2006^18^ | DD, ID | CMA, FISH | 1,170
Altug-Teber et al. 2005^67^ | AS, PW | CMA | 6
Coupry et al. 2004^177^ | RTS | Real-time, quantitative PCR, microsatellite analysis | 22
Kleefstra et al. 2004^178^ | ID, AS, PW | Sequencing, PCR | 253

AS=Angelman’s syndrome (happy puppet syndrome); ASD=autism spectrum disorder (autism, autism susceptibility, MRD1, 2q23.1 deletion syndrome, 2q23.1 duplication syndrome); CMA=chromosomal microarray analysis; DD=developmental delay; FISH=fluorescence in situ hybridization; FX=fragile X (FMR1-related disorders, mental retardation associated with marXq28, marker X syndrome, Martin-Bell syndrome, X-linked mental retardation and macroorchidism); ID=intellectual disability; MLPA=multiplex ligation-dependent probe amplification; PCR=polymerase chain reaction; PW=Prader-Willi syndrome (Prader Labhart Willi syndrome); Rett=Rett syndrome (autism-dementia-ataxia-loss of purposeful hand use syndrome, MECP2-related disorders); RTS=Rubinstein-Taybi syndrome (broad thumb-hallux syndrome); SMS=Smith-Magenis syndrome (17p- syndrome, 17p11.2 monosomy, chromosome 17p11.2 deletion syndrome, chromosome 17p deletion syndrome, deletion 17p syndrome, partial monosomy 17p); VS=velocardiofacial syndrome (22q11.2, conotruncal anomaly, DiGeorge, Shprintzen); WS=Williams syndrome (Beuren syndrome, chromosome 7q11.23 deletion syndrome, elfin facies syndrome, supravalvar aortic stenosis syndrome, Williams-Beuren syndrome)

Table 9 Case series reporting diagnostic yield by developmental disorders

DD Disorder | Number of Studies | Reference
Angelman’s syndrome | 7 | Ahn et al. 2013^97^, Halder et al. 2013^106^, Ellison et al. 2012^40^, Cho et al. 2009^160^, Shen et al. 2007^66^, Altug-Teber et al. 2005^67^, Kleefstra et al. 2004^178^
Autism spectrum disorder | 35 | Yang et al. 2014^69^, Tao et al. 2014^71^, Soden et al 2014^72^, Srivastava et al. 2014^47^, Huguet et al. 2014^84^, Stobbe et al. 2014^89^, Chong et al. 2014^78^, Iglesias et al. 2014^41^, Koshimizu et al. 2013^53^, Nicholl et al. 2014^87^, Battaglia et al. 2013^98^, Esposito et al. 2013^103^, Fan et al. 2013^105^, Marano et al. 2013^111^, Nicholl et al. 2013^113^, Sorte et al. 2013^120^, Winarni et al. 2013^125^, McGrew et al. 2012^131^, Bremer et al. 2011^138^, Roesser 2011^143^, Muscarella et al. 2010^151^, Qiao et al. 2013^116^, Vallespin et al. 2013^123^, Vorsanova et al. 2013^124^, Zarate et al. 2013^126^, Iourov et al. 2012^130^, Tzetis et al. 2012^136^, Bruno et al. 2011^139^, Coulter et al. 2011^23^, Ezugha et al. 2010^148^, Schaefer et al. 2010^152^, Shen et al. 2010^153^, Bucan et al. 2009^159^, Cusco et al. 2009^161^, Shen et al. 2007^66^
Developmental delay | 50 | Lee et al. 2014^68^, Bartnik et al. 2014^73^, Boggula et al. 2014^74^, Byeon et al. 2014^75^, Chong et al. 2014^78^, Iglesias et al. 2014^41^, Pereira et al. 2014^70^, Nicholl et al. 2014^87^, Soden et al 2014^72^, Srivastava et al. 2014^47^, Tao et al. 2014^71^, Uwineza et al. 2014^93^, Yang et al. 2014^69^, Battaglia et al. 2013^98^, Doherty et al. 2013^102^, Hayes et al. 2013^50^, Wiszniewska et al. 2014^96^, Esposito et al. 2013^103^, Fan et al. 2013^105^, Kashevarova et al. 2013^109^, Lee et al. 2013^110^, Marano et al. 2013^111^, Nicholl et al. 2013^113^, Pohovski et al. 2013^114^, Qiao et al. 2013^116^, Rodriguez-Revenga et al. 2013^117^, Shoukier et al. 2013^119^, Vallespin et al. 2013^122^, Zarate et al. 2013^126^, Dos Santos and Freire-Maia 2012^128^, Ellison et al. 2012^40^, Iourov et al. 2012^130^, Tzetis et al. 2012^136^, Bruno et al. 2011^139^, Coulter et al. 2011^23^, Wincent et al. 2011^146^, Bernardini et al. 2010^58^, Ezugha et al. 2010^148^, Gervasini et al. 2010^149^, Manolakos et al. 2010^150^, Auber et al. 2009^156^, Dutta et al. 2009^162^, Hochstenbach et al. 2009^166^, Shahdadpuri et al. 2009^169^, Ballif et al. 2007^65^, Baris et al. 2007^172^, de Souza et al. 2007^173^, Newman et al. 2007^174^, Shen et al. 2007^66^, Rauch et al. 2006^18^
Fragile X syndrome | 14 | Chaudhary et al. 2014^76^, Fatima et al. 2014^81^, Doherty et al. 2013^102^, Esposito et al. 2013^103^, Essop and Krause 2013^104^, Jorge et al. 2013^108^, Zarate et al. 2013^126^, Rooms et al. 2011^144^, Dave et al. 2010^147^, Filipovic-Sadic et al. 2010^60^, Bhowmik et al. 2009^158^, Coffee et al. 2009^61^, Dutta et al. 2009^162^, Hu et al. 2009^62^
Intellectual disability | 85 | Pereira et al. 2014^70^, Bartnik et al. 2014^73^, Boggula et al. 2014^74^, Byeon et al. 2014^75^, Chaudhary et al. 2014^76^, Cheon et al. 2014^77^, Chong et al. 2014^78^, Coutton et al. 2014^79^, Fatima et al. 2014^81^, Gilissen et al. 2014^82^, Helsmoortel et al. 2014^83^, Iglesias et al. 2014^41^, Medina et al. 2014^86^, Nicholl et al. 2014^87^, Palmer et al. 2014^88^, Pereira et al. 2014^70^, Soden et al 2014^72^, Tao et al. 2014^71^, Tucker et al. 2014^90^, Utine et al. 2014^92^, Uwineza et al. 2014^93^, Vergult et al. 2014^94^, Willemsen and Kleefstra 2014^95^, Wiszniewska et al. 2014^96^, Yang et al. 2014^69^, Behjati et al. 2013^99^, Behjati et al. 2013^100^, Jain et al. 2013^107^, Tos et al. 2013^121^, Hochstenbach et al. 2012^129^, Rafati et al. 2012^132^, Rafati et al. 2012^133^, Utine et al. 2012^137^, Hannibal et al. 2011^140^, Rana et al. 2011^142^, Shawky et al. 2011^145^, Siggberg et al. 2010^154^, Xiang et al. 2010^155^, Bruno et al. 2009^42^, Esposito et al. 2013^103^, Essop and Krause 2013^104^, Jorge et al. 2013^108^, Kashevarova et al. 2013^109^, Lee et al. 2013^110^, Marano et al. 2013^111^, Mundhofir et al. 2013^112^, Nicholl et al. 2013^113^, Pohovski et al. 2013^114^, Qiao et al. 2013^116^, Rodriguez-Revenga et al. 2013^117^, Shoukier et al. 2013^119^, Vallespin et al. 2013^122^, Vallespin et al. 2013^123^, Vorsanova et al. 2013^124^, Zarate et al. 2013^126^, Aradhya et al. 2012^127^, Dos Santos and Freire-Maia 2012^128^, Ellison et al. 2012^40^, Iourov et al. 2012^130^, Tos et al. 2012^135^, Tzetis et al. 2012^136^, Bruno et al. 2011^139^, Coulter et al. 2011^23^, Hayashi et al. 2011^141^, Rooms et al. 2011^144^, Bernardini et al. 2010^58^, Dave et al. 2010^147^, Ezugha et al. 2010^148^, Manolakos et al. 2010^150^, Auber et al. 2009^156^, Cho et al. 2009^160^, Dutta et al. 2009^162^, Friedman et al. 2009^163^, Gijsbers et al. 2009^164^, Giorda et al. 2009^165^, Hochstenbach et al. 2009^166^, Koolen et al. 2009^167^, McMullan et al. 2009^168^, Utine et al. 2009^170^, Mandal et al. 2009^171^, Baris et al. 2007^172^, de Souza et al. 2007^173^, Shen et al. 2007^66^, Rauch et al. 2006^18^, Kleefstra et al. 2004^178^
Prader-Willi syndrome | 9 | Boggula et al. 2014^74^, Kleefstra et al. 2004^178^, Tuysuz et al. 2014^91^, Ahn et al. 2013^97^, Halder et al. 2013^106^, Altug-Teber et al. 2005^67^, Ellison et al. 2012^40^, Cho et al. 2009^160^, Shen et al. 2007^66^
Rett Syndrome | 4 | Kalman et al. 2014^48^, Pratt et al. 2013^115^, Splendore et al. 2012^134^, Baris and Battaloglu 2009^157^
Smith-Magenis syndrome | 4 | Ahn et al. 2013^97^, Dubourg et al. 2014^80^, Ellison et al. 2012^40^, Truong et al. 2008^64^
Rubinstein-Taybi syndrome | 3 | Lee et al. 2014^85^, Gervasini et al. 2010^149^, Coupry et al. 2004^177^
Velocardiofacial syndrome | 5 | Del Carmen et al. 2013^101^, Ellison et al. 2012^40^, Cho et al. 2009^160^, Sandrin-Garcia et al. 2007^175^, Shen et al. 2007^66^
Williams syndrome | 6 | Ellison et al. 2012^40^, Cho et al. 2009^160^, de Souza et al. 2007^173^, Shen et al. 2007^66^, van Hagen et al. 2007^176^, Saad et al. 2013^118^

Given that most of the genetic tests relevant to this report are intended to establish an etiologic diagnosis and rarely used in isolation to confirm a clinical diagnosis (e.g., ASD, ID, Angelman syndrome, velocardiofacial syndrome), we did not expect to identify many studies that reported outcomes addressing clinical validity, such as clinical sensitivity or specificity, clinical predictive values, and diagnostic odds ratios. In fact, we only found one study that addressed the clinical validity of a genetic test. Jiao and colleagues (2011) conducted a case-control study among 18 patients with ASD to evaluate the accuracy (sensitivity and specificity) of a diagnostic model based on SNPs and magnetic resonance imaging in predicting ASD subtypes.46

Our search identified 20 studies that addressed analytic validity issues (Table 6). These studies were intended to validate the analytic characteristics of one or more new tests for detecting genetic variants associated with DDs. Reported performance measures include analytic sensitivity or specificity, positive and negative predictive values, receiver operator characteristic (ROC) curves and area under the curve (AUC), reference range, repeatability, precision, concordance, and signal-to-noise ratio. The majority of the studies in Table 6 evaluated polymerase chain reaction (PCR) or chromosomal microarray analysis (CMA). They are either case-control studies or case series. Table 7 is a summary of the analytic validity studies organized by DD conditions. Many of these studies addressed genetic testing for multiple conditions. Fragile X syndrome was the most studied condition.

For this Technical Brief, we identified 129 case series that reported on the diagnostic yield of a genetic test. Diagnostic yield is calculated as the number of patients who had a “causal,” “pathogenic,” or “clinically significant” genetic aberration detected by the test, divided by the total number of patients tested. Although diagnostic yield indicates the percentage of patients being tested who ultimately reach a diagnosis, it does not reveal whether the diagnoses reached are correct or whether the targeted genetic aberration is truly causal, pathogenic, or clinically significant. Although improved diagnostic yield is often used by researchers as evidence to support the use of genetic tests, this improvement does not necessarily lead to improved health outcomes.

The diagnostic yield studies we identified are summarized in Table 8. These studies include those comparing diagnostic yields of two or more testing methods and those validating a new testing method. CMA was the most prevalent genetic test method (in 66 studies), followed by PCR (in 34 studies). Most of the diagnostic yield studies addressed multiple DD conditions. As Table 9 demonstrates, ID was the most studied DD (in 85 studies), followed by developmental delay (in 50 studies) and ASD (in 35 studies).

Additionally, we identified more than 200 studies (not including single-patient or single-family case reports) that investigated any association between a genetic marker (genotype) and a DD disorder or its physical and mental characteristics (phenotype). These genotype-phenotype association studies are exploratory in nature. They were not intended to validate a genetic test. Instead, they used genetic tests as research tools. These studies generate hypotheses and provide valuable input for developing future genotype-phenotype associations. However, it is still premature to consider the findings of these studies in building the evidence chain for addressing genetic tests’ clinical utility. Therefore, we do not report these studies in this Technical Brief.

## Studies Addressing Economic, Ethical, Social, and Legal Issues (Guiding Question 4)

For this Technical Brief, we searched for studies that addressed economic issues including cost-effectiveness of genetic testing for DDs. Our search did not identify any economic study conducted in the U.S. context. We identified several cost-effectiveness analyses conducted in other countries. We excluded these studies as the findings are not applicable to the United States because of the significant differences in the countries’ economic and health care systems.

We did not identify any empirical study focusing on ethical or legal issues regarding genetic testing in the context of DD care. Limited discussions about ethical concerns (e.g., how to deal with genetic abnormalities unrelated to DDs that are detected in genome-wide testing) may exist in narrative reviews and clinical studies.31 However, we did not include studies that provide only general discussions of ethical issues that may apply to DDs and non-DDs.

## Clinical Guidelines (Guiding Question 4)

For this Technical Brief, we searched for clinical practice guidelines relevant to genetic testing for DDs that were published by medical groups or professional societies. We identified 16 relevant guidelines.3,4,19,21,27,179–189 Table 10 is a summary of the seven guidelines that provide recommendations regarding use of genetic testing for evaluating DDs. Because genetic research and testing methods for DDs change rapidly, we did not include guidelines published beyond the last 5 years. Guidelines published before this period may be useful for some readers who are interested in certain DDs or genetic tests. Readers should always use their own judgment to determine the relevance of older guidelines to the topics of their interest. Guidelines that focus only on interpreting genetic testing results are also not included in Table 10. Because of the differences in their purposes and methodologies, these guidelines provide different recommendations. ASD or ID are addressed in six of the seven guidelines. CMA testing for CNV is recommended for use in evaluating individuals with ASD, ID, GDD, or certain congenital anomalies in four guidelines.3,19,21,27 See Table 10 for detailed recommendations.

Table 10 Summary of recent clinical guidelines

Reference | Purpose | Disorders Addressed | Recommendation Relevant to Genetic Testing
Moeschler et al. 2014^3^ American Academy of Pediatrics Committee on Genetics | ID or GDD | To describe an optimal medical genetics evaluation of the child with ID or GDD. This report does not cover children with ASD who also have ID as a co-occurring disability or children with a single-domain developmental delay. | - If a specific diagnosis is suspected, arrange for the appropriate diagnostic studies to confirm including single-gene tests or chromosomal microarray test.; - If diagnosis is unknown and no clinical diagnosis is strongly suspected, begin the stepwise evaluation process:; a. CMA should be performed in all.; b. metabolic testing should be considered and should include serum total homocysteine, acyl-carnitine profile, amino acids; and urine organic acids, glycosaminoglycans, oligosaccharides, purines, pyrimidines, guanidinoacetate/creatine metabolites.; c. Fragile X testing should be performed in all.; - If no diagnosis is established:; a. Male gender and family history suggestive X-linkage, complete XLID panel that contains genes causal of nonsyndromic XLID and complete high density X-CMA. Consider X-inactivation skewing in the mother of the proband.; b. Female gender: complete MECP2 deletion, duplication, and sequencing study.; If the specific diagnosis is certain, provide genetic counseling services by a certified genetic counselor.
Schaefer et al. 2013^19^ American College of Medical Genetics and Genomics | ASD | To present a tiered evaluation approach of the etiology of ASD based on current evidence to assist clinicians | - A genetic evaluation should be offered to every person with ASD.; - In situations in which 3rd-party payers will cover cytogenetic studies but not CMA testing, a conventional chromosomal analysis is preferable to no cytogenetic testing at all.; - Because 1 ASD hotspot (16p11.2) has been reported to have CNVs occurring in 0.5% to 1% of all individuals with ASD, CMA is now recommended as a 1st-tier test over karyotyping.; - There is adequate evidence to suggest testing for fragile X syndrome, methyl-CPG-binding protein 2 spectrum disorders, and PTEN-related conditions in patients with ASD with no other identifiable etiology.; - Routine testing of females with ASD for fragile X does not meet evidence-based criteria. However, serious consideration should be given to order fragile X testing in females with ASD when prompted by clinical parameters such as a phenotype compatible with fragile X, a family history positive for X-linked neurodevelopmental disorders, or premature ovarian insufficiency, ataxia, or tremors in close relatives.; - Given the current evidence, MECP2 testing of males with autism is not recommended. However, geneticists should be alert to the features of MECP2 duplications (drooling, recurrent respiratory infections, hypotonic facies) and consider MECP2 duplication testing in boys with autism and such features.; - It is suggested that PTEN testing be reserved for patients with ASD with a head circumference above the 98th percentile. When a family history is consistent with X linked inheritance and the patient has cognitive impairments, an X-linked intellectual disability gene panel is a consideration.; - Testing for mitochondrial disorders in persons with ASD is recommended only if supporting symptoms or laboratory abnormalities are present.; - Genetic tests that have been suggested in the etiologic evaluation of ASD but currently with insufficient evidence to recommend routine testing include: CDLK5 testing, cholesterol/7 dehydrocholesterol, chromosome 15 methylation/UBE3A gene testing, methylation/epigenetic testing, mitochondrial gene sequencing/oligoarray, NSD1 testing, reduction-oxidation studies, purine/pyrimidine metabolism, folate-sensitive fragile sites, and selected neurometabolic screening.
Finucane et al. 2012^190^ National Society of Genetic Counselors | FMR1-associated disorders | To assist genetic counselors in providing accurate risk assessment and appropriate educational and supportive counseling for individuals with positive test results and families affected by FMR1-associated disorders | No specific genetic test was recommended by this guidelines authors.
National Institute for Health and Care Excellence (UK) 2011^181^ | ASD | To provide information on the recognition, referral, and diagnosis of autism in children and young people from birth through 19 years of age | - Consider whether the child or young person may have medical or genetic problems and disorder (e.g., chromosome disorders, genetic abnormalities including fragile X) as a coexisting condition and, if suspected, carry out appropriate assessments and referrals.; - Do not routinely perform any medical investigations as part of an autism diagnostic assessment but consider the following in individual circumstances and based on physical examination, clinical judgment and the child or young person’s profile: genetic tests, as recommended by your regional genetics center, if there are specific dysmorphic features, congenital anomalies and/or evidence of intellectual disability.
Manning et al. 2010^27^ American College of Medical Genetics and Genomics | ID, ASD, GDD, or congenital anomalies | To provide guidance for health care providers treating patients with developmental delays, ID, congenital anomalies, dysmorphic features, and ASD in determining the need for array-based genetic testing for detecting chromosomal abnormalities | - CMA testing for CNVs is recommended as a 1st-line test in the initial postnatal evaluation of individuals with the following:; ○ Multiple anomalies not specific to a well-delineated genetic syndrome; ○ Apparently nonsyndromic developmental delays or intellectual disabilities; ○ ASD; - Appropriate followup is recommended in cases of chromosome imbalance identified by CMA, to include cytogenetic/FISH studies of the patient, parental evaluation, and clinical genetic evaluation and counseling.
Miller et al. 2010^21^ International Standard Cytogenomic Array Consortium | ID, ASD, or multiple congenital anomalies | To evaluate the benefits and limitations of CMA as compared with G-banded karyotyping for detecting pathogenic genomic imbalances in patients with ID, ASD, and/or multiple congenital anomalies | The authors recommended offering CMA as the 1st-tier genetic test, in place of G-banded karyotype, for patients with unexplained developmental delays/ID, ASD, or multiple congenital anomalies.
Ministry of Health, Singapore 2010^182^ | ASD | To assist practitioners in Singapore who are involved in any of the following: surveillance, screening, and early identification, referral for assessment, diagnosis and intervention of children with ASD | - Children with ASD with the following features should have a genetic evaluation: microencephaly or macroencephaly, a positive family history of a genetic syndrome, dysmorphic features.; - Children with ASD may be offered high-resolution chromosomal studies and DNA analysis to look for an associated medical condition after diagnosis.

ASD=autism spectrum disorder; CMA= chromosomal microarray analysis; CNV= copy-number variation; FISH=fluorescent in situ hybridization; GDD=global developmental delay; ID=intellectual disability; PTEN= phosphate and tensin homolog; XLID= X-linked intellectual disability

## Emerging Technologies and Ongoing Trials (Guiding Question 4)

The GTR data we collected did not allow an analysis to predict which type of genetic tests will be more prevalent in DD care in the future. We did not identify any data-based analysis that predicted the trend of genetic technologies for DD diagnosis or screening. However, our interview of the Key Informants suggested that the whole exome or genome sequencing may be increasingly used in the context of DD care as the cost for these tests continue to drop. See the section on whole-exome and whole-genome sequencing in Appendix B for more information on these technologies and their technical capabilities. Additional references are provided in that section for a more in-depth overview of the sequencing technologies, including their potential advantages and limitations.

Our search of the National Clinical Trials online database (www.ClinicalTrials.gov) identified 10 ongoing clinical trials. The purposes of these trials vary significantly. Six trials are intended to explore the genetic mechanisms or genotype-phenotype association for ASD (ClinicalTrials.gov identifiers NCT01686685, NCT01749670, NCT01646866, NCT01770548) or ID (NCT01867554, NCT02136849). Two trials are purported to validate the algorithm (NCT01810341) or the sample collecting method (NCT01616589) used in a genetic test. Another two trials are intended to study the effectiveness of a treatment in patients selected based on genotyping findings (NCT00768820, NCT00859664). Eight of the 10 trials focus on ADD or ID. Seven of the 10 trials are observational cohort studies. The other three trials include two case-control studies and a nonrandomized, parallel assignment study. These trials are summarized in Appendix E.

## Systematic Reviews and Technology Assessment Reports (Guiding Question 4)

We searched for systematic reviews and health technology assessment reports relevant to genetic testing for DD, ID, and ASD that were published by professional societies in the past 5 years. Our search identified three relevant documents. These systematic reviews addressed diagnostic yields of microarray-based comparative genomic hybridization (aCGH), testing for X-linked ID genes, FMR1 testing, MeCP2 testing, and conventional G-banded karyotyping for developmental delays, ID, or ASD. The main findings of these reviews are summarized in Table 11. We did not include systematic reviews or technology assessment reports published in non-English languages. We also excluded proprietary technology assessment reports that are not publicly accessible. Because genetic research and testing methods for DDs change rapidly, we did not search for systematic reviews or technology assessment reports published beyond the most recent 5 years.

Table 11 Summary of recent systematic reviews and technology assessment reports

Reference | Purpose | Resources Searched and Inclusion Criteria | Findings
Hochstenbach et al. 2011^191^ | To review the contributions and limitations of genome-wide array-based identification of CNVs in the clinical diagnostic evaluation of patients with MR and other brain-related disorders | Publications were retrieved from the PubMed database of the National Center for Biotechnology Information. The studies were included only if (1) the clinical diagnosis was made according to international standards, (2) segmental aneuploidies detected by array-based methods was validated by an independent method, or (3) it was possible to relate the aberrations to specific patients. | In unselected MR referrals, a causative genomic gain or loss is detected in 14% to18% of cases. Usually, such CNVs arise de novo, are not found in healthy subjects, and have a major impact on the phenotype by altering the dosage of multiple genes. The expected diagnostic yield for patients with autism is about 5% to 10% in nonsyndromic and 10% to 20% in syndromic patients. Exome sequencing in patients with MR or autism revealed de novo mutations in protein coding genes in 60% and 20% of cases, respectively.
Michelson et al. 2011^20^ | To systematically review the evidence concerning the diagnostic yield of genetic and metabolic evaluation of children with GDD/ID | Relevant literature was reviewed, abstracted, and classified according to the 4-tiered American Academy of Neurology classification of evidence scheme | In patients with GDD/ID, microarray testing is diagnostic on average in 7.8%, G-banded karyotyping is abnormal in at least 4%, and subtelomeric fluorescence in situ hybridization is positive in 3.5%. Testing for X-linked ID genes has a yield of up to 42% in males with an appropriate family history. FMR1 testing shows full expansion in at least 2% of patients with mild to moderate GDD/ID, and MeCP2 testing is diagnostic in 1.5% of females with moderate to severe GDD/ID.
Sagoo et al. 2009^192^ | To update a previous systematic review evaluating array-based comparative genomic hybridization used in patients with ID and congenital anomalies | MEDLINE, EMBASE, and Web of Science databases were searched during March 2008 with both free-text and MeSH terms. No language or other search restrictions were imposed and reference lists of primary studies were checked for additional references. | The overall diagnostic yield of causal abnormalities was 10%. The overall number needed to test to identify an extra causal abnormality was 10. The overall false-positive yield of noncausal abnormalities was 7%.

CNVs=copy number variation; GDD=global developmental delay; ID=intellectual disability; MR=mental retardation