# Background

Recent decades have witnessed numerous advances in genetics research highlighting the importance of genetic factors as an etiology for developmental disabilities (DDs). Given the rapid diffusion of advanced genetic tests for diagnosing DDs or determining their etiology, the Agency for Healthcare Research and Quality (AHRQ) commissioned the ECRI Institute–Penn Medicine Evidence-based Practice Center to prepare this Technical Brief to provide an overview of these tests. The brief summarizes information on tests that are clinically available in the United States. The brief also identifies existing evidence addressing the clinical utility of genetic tests for DDs. An evidence map is presented to outline evidence gaps on the subject and provide guidance for future research.

## Developmental Disabilities

DDs are a group of conditions associated with functional impairment in physical, learning, language, or behavior areas.1 According to this definition, the Centers for Disease Control and Prevention (CDC) categorizes a broad range of conditions as DDs, such as attention-deficit/hyperactivity disorder, autism spectrum disorder (ASD), cerebral palsy, hearing loss, learning disability, intellectual disability (ID), Tourette syndrome, vision impairment, and others.1 The prevalence of DDs is estimated to be more than 15 percent in children 3–17 years of age.2 These disorders, which often require lifelong individual and family support or treatment, have a profound impact on patients, families, and society. DDs can be caused or influenced by a variety of genetic and environmental factors, including gene mutations, mother’s health behaviors (e.g., smoking and drinking) and untreated illness (e.g., phenylketonuria), complications during pregnancy or birth, and the exposure of the pregnant mother or child to infections or environmental toxins.1 The causes of some developmental disabilities (e.g., Down syndrome, fragile X syndrome, fetal alcohol syndrome) are well understood. However, the underlying causes of many other DDs (e.g., ASD, ID) are often unclear and may vary substantially across individuals.

DDs can affect cognitive (including language and non-verbal problem solving), motor, and/or sensory functions. This Technical Brief focuses on genetic tests for evaluating DDs with primarily cognitive impairments, particularly idiopathic, nonsyndromic ID, ASD, and global developmental delay (GDD). Additionally, several DD syndromes were also included in this report based on key stakeholders’ interest. These syndromes include Angelman syndrome, fragile X syndrome, Prader-Willi syndrome, Rett syndrome, Rubinstein-Taybi syndrome, Smith-Magenis syndrome, velocardiofacial syndrome, and Williams syndrome. For patients with these syndromes, manifestations of GDD, ID, or ASD might be the main reason for families to seek evaluation when overt dysmorphic features have not been noted. DDs primarily diagnosed based on sensory or motor impairments (e.g., cerebral palsy, hearing loss, vision impairment) are beyond the scope of this brief. The findings of this Technical Brief should be interpreted as applying only to the DD conditions included in the report.

### Intellectual Disability and Autism Spectrum Disorders

ID is a DD that may present in infancy or early childhood years. The American Association on Intellectual and Developmental Disabilities (AAIDD) defines ID as “a disability characterized by significant limitations both in intellectual functioning and in adaptive behavior as expressed in conceptual, social and practical adaptive skills.”3 ID affects 1 percent to 3 percent of the population worldwide,4,5 and about 0.7 percent of children aged 3–17 years in the United States.2 Clinically, ID is diagnosed using standardized measures of developmental skills. These measures cover the domains of intelligence (IQ), adaptive behavior, and language function.6,7 Because these standardized measures may be less reliable and valid for children younger than 5 years of age, establishing the clinical diagnosis of ID in early childhood can be challenging.3

Some possible causes that have been linked to ID include genetic aberrations, exposure to harmful substances (e.g., alcohol) or infection during pregnancy, complications during birth, acquired brain injury, and preterm birth.8 Managing ID includes family support, family education and counseling, and special educational programs that may begin as early as infancy.9 The goal of treatment is to support the child and family to enable the child to develop to his full potential.

ASD is a complex neurodevelopmental disorder, characterized by impairment in social interaction and communication and restricted, repetitive, and stereotyped patterns of behavior. Symptoms and profiles of children with ASD vary. In the period from 2006 to 2008, studies reported that autism affected 0.74 percent of children aged 3–17 years in the United States.2 In 2010, the Autism and Developmental Disabilities Monitoring Network sites reported that the prevalence of ASD among children aged 8 years was 1.47 percent.10 Both genetic and environment factors (e.g., maternal valproic acid use during pregnancy, congenital rubella) may play a role in ASD development,11 and multiple genes have been found to influence ASD risk.12

ASD diagnosis is based on interviews with the child and family, a review of records and historical information, and examination of the child using standardized instruments (e.g., Autism Behavior Checklist, Autism Diagnostic Interview-Revised, Autism Diagnostic Observation Schedule) to demonstrate presence of core features of ASD. The results of clinical evaluation are compared with the diagnostic criteria included in the fifth edition of the Diagnostic and Statistical Manual of Mental Disorders (DSM-5).13 The diagnosis of ASD in infants and very young children is more difficult because developmental and behavioral assessment of these children may be more challenging. Some core features (e.g., socialization deficits, repetitive behavior, stereotyped movements) may emerge later as the child develops.

Key treatments for children with ASD include structured educational and behavioral interventions (e.g., applied behavioral analysis) to address core and associated symptoms and to promote development of social and communication skills. Behavioral interventions and medication may be used to address comorbid symptoms (e.g., anxiety, depression) or severe behavioral problems (e.g., aggression, self-injury).

Because establishing a diagnosis of ID or ASD may be challenging in infants and very young children, the term “global developmental delay” (GDD) is often used to categorize children who are younger than 5 years of age who have a significant delay in two or more developmental domains, including gross or fine motor, speech and language, cognitive, social and personal, and activities of daily living.3,14 Significant delay is defined as performance two standard deviations or more below the mean on age-appropriate, standardized, normal-referenced testing.15 Evaluating developmental delays requires accurate documentation by using norm-referenced and age-appropriate standardized measures of development administered by experienced developmental specialists.3,15 Although GDD suggests a possible future diagnosis of ID and/or ASD, a child with GDD is not necessarily destined to have those conditions.

The prevalence of GDD is unknown, but may be similar to that of ID and ASD. GDD has a heterogeneous etiologic profile and is associated with age-specific deficits in adaptation and learning skills. Both genetic and environmental factors may be associated with GDD.15,16

## Genetic Testing for Developmental Disabilities

Genetic abnormalities have been linked to many DDs. Studies suggest that up to 40 percent of DDs may be caused by some genetic aberration.17,18 Conventional G-banded karyotyping has been used for decades to confirm the diagnosis of DDs (e.g., aneuploidies) that have a well-defined genetic etiology. More recently, new genetic methods (e.g., microarray-based comparative genomic hybridization [aCGH], whole genome or exome sequencing) have been developed and used to detect genetic abnormalities associated with DDs. These newer tests support the examination of genetic information at a higher resolution and may show genetic abnormalities not seen on G-banded karyotyping. In Appendix B, we provide a detailed technical overview to help illustrate how these genetic testing methods work and the main differences between them.

As previously discussed, clinical diagnosis of ID, ASD, or GDD is typically based on clinical manifestations and cognitive and developmental assessment using standardized measures. ID, ASD, and GDD are “functional diagnoses,” which are phenotype-oriented descriptions of DDs. Each of these functional diagnoses includes multiple disorders of different etiologies (e.g., Angelman syndrome, fragile X syndrome, Prader-Willi syndrome, Rett syndrome, Rubinstein-Taybi syndrome, Smith-Magenis syndrome, velocardiofacial syndrome, and Williams syndrome). When genetic tests are used to assess patients diagnosed with ID, ASD, or GDD, they are not used to confirm these functional diagnoses. Instead, these tests are used to establish an “etiologic diagnosis,” that is, whether a patient who has an apparent functional diagnosis carries a specific genetic variant.

Etiologic diagnosis is a genotype-oriented description of genetic disorders and may be viewed as an early stage of defining a clinical disorder that has not yet been well understood or defined. A new etiologic diagnosis (i.e., the new genetic variant identified) can be further evaluated among individuals with the genotype in common to determine whether or not they share a common phenotype. If they share a common phenotype, a new genetic disorder may be defined and the genotype becomes part of the clinical definition of the disorder (e.g., fragile X syndrome).

Proposed benefits of establishing an etiologic diagnosis in patients with ID, ASD, or GDD include the following:3,19–26

- Clarifying a genetic cause and improving the psychosocial outcomes (e.g., improved knowledge and sense of empowerment) for patients and their families
- Providing prognosis or expected clinical course
- Evaluating recurrence risks and helping families in reproductive decisionmaking
- Refining treatment options
- Avoiding unnecessary and redundant diagnostic tests
- Identifying associated medical risks to prevent morbidity
- Providing condition-specific family support
- Facilitating acquisition of needed services and improving access to research treatment protocols

Because of these potential benefits, genetic tests are being used at an increasingly rapid rate. Medical genetics groups now recommend chromosomal microarray analysis (CMA) as a first-line genetic test to identify genetic mutations in children with multiple anomalies not specific to well-delineated syndromes, nonsyndromic DD/ID, and ASD.3,19,21,27 Payers have seen a significant number of claims for genetic testing in children with suspected or proven DDs.28 However, little evidence from controlled studies exists to directly link genetic testing to health outcomes.29 Published studies have reported superior diagnostic yields of newer genetic tests (e.g., aCGH) in identifying DD-related genetic abnormalities, and some have identified the impact of the tests on medical management (e.g., medical referrals, diagnostic imaging, further laboratory testing).20–26 However, these findings are not sufficient for drawing a conclusion that use of the tests will lead to improved health outcomes (further discussion on this issue is provided in a later section, Establishing the Clinical Utility of Genetic Tests).

The impact of increased use of genetic tests, such as CMA, on health care costs is unclear. Advanced genetic tests are generally more expensive to perform than conventional G-banded karyotyping or other clinical tests.30 Identification of genetic abnormalities on germline cells may also lead to genetic testing in patients’ relatives, which further expands the pool of children for testing and magnifies the potential cost impact. Conversely, the potential increased diagnostic yield of advanced genetic tests may reduce the number of other clinical tests or services used to identify genetic causes of DDs. Besides the uncertain clinical utility and concerns about economic impact, ethical issues—such as how to deal with genetic abnormalities unrelated to DD that are detected in genome-wide CMA—also remain controversial.31

### Availability of Genetic Tests for Developmental Disabilities in the United States

Genetic tests become clinically available in the United States via one of two pathways. A genetic test may reach the market as a commercially distributed test kit approved or cleared by the U.S. Food and Drug Administration (FDA) or as a laboratory-developed test (LDT).32,33 Test kits cleared or approved by FDA include all reagents and instructions needed to complete the test procedure and interpret the results. These test kits can be used in multiple laboratories. LDTs are developed in laboratories using either FDA-regulated or self-developed analyte-specific reagents and are intended for performance solely in the test developer’s laboratory.

The U.S. Centers for Medicare & Medicaid Services regulates laboratories that perform LDTs under the Clinical Laboratory Improvement Amendments of 1988 (CLIA).32,33 Under CLIA regulations, facilities that perform tests on “materials derived from the human body for the purpose of providing information for the diagnosis, prevention, or treatment of any disease or impairment of, or the assessment of the health of, human beings” must obtain a certificate from the CLIA program. The requirements for CLIA certification are based on the complexity of the tests. LDTs compose the majority of the genetic tests that have become available to clinical practice.33 Laboratories offering LDTs must be licensed as high-complexity clinical laboratories under CLIA regulations. A technology assessment report suggested that genetic tests for diagnosing DDs are primarily available as LDTs.29

Historically, FDA has exercised regulatory enforcement discretion over LDTs because they were relatively simple lab tests. As LDTs become more complex and proliferate in clinical use, the agency is taking steps to actively regulate LDTs. On October 3, 2014, FDA published two draft guidance documents regarding oversight of LDTs, titled “Framework for Regulatory Oversight of Laboratory Developed Tests (LDTs)” and “FDA Notification and Medical Device Reporting for Laboratory Developed Tests (LDTs).”34,35 Under the proposed regulatory framework, LDTs will fall into one of the three categories: LDTs subject to full enforcement discretion; LDTs subject to partial enforcement discretion; and LDTs subject to full FDA regulation. Once the proposed FDA guidance documents are finalized, it will become clearer how genetic tests for DDs will be regulated.

## Evaluating the Clinical Utility of Genetic Tests

The clinical utility of a medical test refers to how likely the test is to affect clinical decisions and ultimately improve patient outcomes. The ideal type of evidence for establishing clinical utility is from high-quality randomized controlled trials (RCTs) that compare health outcomes in patients who undergo the test to those in patients who do not. In reality, however, this type of RCT is rarely conducted.32,33,36 To answer the ultimate clinical utility question—whether use of the test will improve health outcomes—an inference-based chain of evidence often needs to be established.36,37 Establishing this chain of evidence involves assessing the analytic validity and clinical validity of the test of interest and establishing an indirect evidence link to clinical outcomes.

Analytic validity refers to how accurately and reliably the test measures the analyte of interest, such as a gene or chromosomal variant. Analytic validity is a function of many factors such as analytic accuracy, precision, analytic sensitivity and specificity, robustness, and reference range or normal values. The technical terms for analytic validity are defined in Appendix C of this report, Definition of Terms.

Clinical validity, also known as diagnostic accuracy, refers to how accurately the test detects or predicts the clinical condition of interest. Clinical validity is usually described in terms of clinical sensitivity, clinical specificity, positive and negative predictive values, likelihood ratios, diagnostic odds ratios, and the area under a receiver operator characteristic (ROC) curve. These technical terms related to clinical validity are also defined in Appendix C of this report. To address clinical validity, diagnostic cohort studies that use a gold-standard reference method are ideal.

When direct evidence does not exist or is insufficient to draw a reliable conclusion on whether testing improves health outcomes, addressing clinical validity and analytic validity may provide indirect evidence on the likelihood of a test affecting health outcomes. For example, if evidence shows that a test does not have adequate analytic validity, then the test is not likely to have adequate clinical validity. If a test does not have adequate clinical validity, it will have limited impact on treatment or family decisions. If a test does not change clinical or family decisions, it is unlikely to affect health outcomes.

## Guiding Questions and Scope of Work

To meet this Technical Brief’s objectives, we used a series of questions to guide our efforts in collecting appropriate information. These guiding questions fall into four categories:

1. Description of genetic tests for diagnosing or determining the etiology of DDs
  a. What genetic tests for diagnosing or determining the etiology of DDs are available for clinical practice in the United States?
  b. What genetic techniques or analysis methods (e.g., CMA, subtelomeric fluorescence in situ hybridization [FISH], whole genome or exome sequencing) are used in these tests? How do these types of techniques or methods work?
2. The context in which genetic tests are used for diagnosing or determining the etiology of DDs:
  a. What is the regulatory status (i.e., FDA clearance or approval status, CLIA certification of the test provider) of the tests?
  b. What kinds of credentials (i.e., training, certification) are required for interpreting test results?
  c. Who are the providers ordering the tests and using their results?
3. State of the evidence on genetic tests for diagnosing or determining the etiology of DDs
  a. What are the DD conditions addressed in studies of these tests?
  b. What are the study designs used?
  c. What outcomes are reported?
    i. What data have been reported in the literature about the analytic validity of the tests?
    ii. What data have been reported in the literature about the clinical validity of the tests?
    iii. What data have been reported in the literature about the clinical utility of the tests?
    iv. What are the potential safety issues or harms related to the tests?
4. What are the important issues raised by genetic tests for diagnosing or determining the etiology of DDs?
  a. What are the proposed advantages and disadvantages of these tests compared with standard-of-care diagnostic methods?
  b. What recommendations do clinical practice guidelines include regarding the use of the tests?
  c. Given the current evidence status, what are the implications of the tests in terms of ethics, privacy, equity, cost, or economic efficiency?
  d. What are the current evidence gaps and potential areas of future research?
  e. What ongoing clinical trials are evaluating the clinical utility of the tests?
  f. What genetic tests or testing methods under research may become clinically available for diagnosing DDs in the near future?

The scope of work for this Technical Brief is described below by the population, interventions, comparators, and outcomes of interest. This scope reflects the ECRI Institute–Penn Medicine EPC team’s current thinking and incorporates the input from AHRQ, the Technical Brief’s topic nominators, the Key Informants, and Peer Reviewers.

Population: Children with DDs (e.g., ID and ASD) and their families (e.g., their siblings who may have the same disorder)

As previously discussed, this Technical Brief primarily focuses on patients with idiopathic or unexplained DDs, particularly IDs, ASD, or GDDs. These patients have clinical manifestations but may not have shown any distinct dysmorphic or syndromic features. Several better-defined DD syndromes are also included in the brief. These syndromes include Angelman syndrome, fragile X syndrome, Prader-Willi syndrome, Rett syndrome, Rubinstein-Taybi syndrome, Smith-Magenis syndrome, velocardiofacial syndrome, and Williams syndrome. DDs that are typically diagnosed based upon motor or sensory impairments (e.g., cerebral palsy, hearing loss, vision impairment) or based on conventional G-banded karyotyping (e.g., aneuploidies) are beyond the scope of this report.

Interventions: Genetic tests for diagnosing DDs

This Technical Brief includes only tests that are available in the United States, either as FDA-cleared or FDA-approved test kits or as an LDT provided by a CLIA-certified laboratory. We primarily focus on CMA, including aCGH and single nucleotide polymorphism (SNP) assays, because use of these tests is widespread in clinical practice and because medical genetics groups have recommended the tests for identifying genetic variants (e.g., copy number variations) in children with DDs.

Other types of genetic tests within the scope of work include polymerase chain reaction (PCR)-based tests (e.g., quantitative PCR); multiplex ligation-dependent probe amplification; Southern blot; whole genome or exome sequencing (e.g., using the Sanger method or next-generation sequencing); FISH, including subtelomeric FISH; and tests used for methylation analysis, deletion/duplication analysis, and uniparental disomy study. Conventional G-banded karyotyping is beyond the scope of work for this report.

Comparators: Comparators may vary across DDs and assessment purposes (e.g., clinical utility, clinical validity). For example, for assessing the clinical utility of a genetic test for determining the genetic etiology of ID, an appropriate comparator can be the standard-of-care diagnostic method without genetic testing. The standard-of-care method may include a physical examination by a clinician, a developmental assessment using standardized instruments (e.g., Wechsler Preschool and Primary Scale of Intelligence, Wechsler Intelligence Scales for Children, and Stanford-Binet Intelligence Scales), and other diagnostic tests (e.g., neuroimaging, metabolic studies).28

Outcomes: Patient-centered health outcomes and intermediate outcomes including changes in clinical decisions (e.g., refining treatment options, ordering other tests, referring patients to other specialists) or family reproductive decisions, diagnostic accuracy (e.g., sensitivity, specificity, positive and negative predict values), and parameters for measuring the analytic validity of a test.

Relevant outcomes may vary across different DDs. For example, for ASD, relevant outcomes may include reduction in autism symptom severity and improvement in language or adaptive behavior measured by a validated or standardized instrument (e.g., the Autism Diagnostic Observation Schedule, the MacArthur-Bates Communicative Development Inventories, Vineland Adaptive Behavior Scales). Outcomes relevant to ID include changes in cognition, remote memory, problem solving, understanding of relationships, social interaction, communication, self-care, and activities of daily living.