# Appendix Reference List

1 Cambell NA, Reece JB, Mitchell LG. Biology. 5th ed. Menlo Park (CA). Benjamin Cummings. 1999.
2 Hartl DL, Jones EW. Genetics: analysis of genes and genomes. 5th ed. Sudbury (MA). Jones and Bartlett Publishers. 2001.
3 Genetics home reference: Down syndrome. Bethesda (MD). U.S. National Library of Medicine (NLM). 2014. Sep. 29. http://ghr.nlm.nih.gov/condition/down-syndrome. Accessed 2014 Sep 30.
4 Genetics home reference: Rett syndrome. Bethesda (MD). U.S. National Library of Medicine (NLM). 2014. Sep. 29. http://ghr.nlm.nih.gov/condition/rett-syndrome. Accessed 2014 Sep 30.
5 Genetics home reference: MECP2. Bethesda (MD). U.S. National Library of Medicine (NLM). 2014. Sep. 29. http://ghr.nlm.nih.gov/gene/MECP2. Accessed 2014 Sep 30.
6 Genetics home reference: glossary: copy number variation. Bethesda (MD). U.S. National Library of Medicine (NLM). 2014. Sep. 29. http://ghr.nlm.nih.gov/glossary=copynumbervariation. Accessed 2014 Sep 30.
7 Bickmore WA. Karyotype analysis and chromosome banding. Encyclopedia of life sciences. London (UK). Nature Publishing Group. 2001:1-7. Also available: http://www.unioviedo.es/esr/pp/bandmethods.pdf.
8 Fluorescence In Situ Hybridization (FISH). National Human Genome Research Institute. 2011. Oct. 13. http://www.genome.gov/10000206. Accessed 2014 Oct 02.
9 Beaudet AL. The utility of chromosomal microarray analysis in developmental and behavioral pediatrics. Child Dev. Jan–Feb. 2013;84(1):121-32. [pmid: 23311723].
10 Theisen A. Microarray-based comparative genomic hybridization (aCGH). Nat Educ. 2008;1(1):45.
11 Microarray-based comparative genomic hybridization (array CGH). Rare Chromosome Disorder Support Group. 2013:12. Also available: http://www.rarechromo.org/information/other/array%20cgh%20ftnw.pdf.
12 Genetics home reference: what are single nucleotide polymorphisms (SNPs)?. Bethesda (MD). U.S. National Library of Medicine (NLM). 2014. Sep. 29. http://ghr.nlm.nih.gov/handbook/genomicresearch/snp. Accessed 2014 Sep 30.
13 LaFramboise T. Single nucleotide polymorphism arrays: a decade of biological, computational and technological advances. Nucleic Acids Res. Jul. 2009;37:4181-93. [pmid: 19570852].
14 Sherry ST, Ward MH, Kholodov M, et al. dbSNP: the NCBI database of genetic variation. Nucleic Acids Res. Jan. 1. 2001;29:308-11. [pmid: 11125122].
15 Marian AJ. Sequencing your genome: what does it mean?. Methodist Debakey Cardiovasc J. Jan–Mar. 2014;10:3-6. [pmid: 24932355].
16 Genetics home reference: what advances are being made in DNA sequencing. Bethesda (MD). U.S. National Library of Medicine (NLM). 2014. Sep. 29. http://ghr.nlm.nih.gov/handbook/genomicresearch/sequencing. Accessed 2014 Oct 01.
17 Medical genetics test details: whole exome sequencing. Houston (TX). Baylor College of Medicine. https://www.bcm.edu/research/medical-genetics-labs/test_detail.cfm?testcode=1500. Accessed 2014 Oct 01.
18 Rabbani B, Tekin M, Mahdieh N. The promise of whole-exome sequencing in medical genetics. J Hum Genet. Jan. 2014;59(1):5-15. [pmid: 24196381].
19 Ng SB, Turner EH, Robertson PD, et al. Targeted capture and massively parallel sequencing of 12 human exomes. Nature. Sep. 10. 2009;461(7261):272-6. [pmid: 19684571].
20 Teer JK, Mullikin JC. Exome sequencing: the sweet spot before whole genomes. Hum Mol Genet. Oct. 15. 2010;19:R145-51. [pmid: 20705737].
21 Chorev M, Carmel L. The function of introns. Front Genet. 2012;3:55. [pmid: 22518112].
22 Beachy, et al. Assessing genomic sequencing information for health care decision making: workshop summary. Washington (DC). National Academies Press. 2014.
23 Policy statement: points to consider in the clinical application of genomic sequencing. Bethesda (MD). American College of Medical Genetics and Genomics (ACMG). 2012. May. 15. 4 p. Also available: https://www.acmg.net/StaticContent/PPG/Clinical_Application_of_Genomic_Sequencing.pdf.
24 Dewey FE, Grove ME, Pan C, et al. Clinical interpretation and implications of whole-genome sequencing. JAMA. Mar. 12. 2014;311:1035-45. [pmid: 24618965].
25 PCR fact sheet. Bethesda (MD). National Human Genome Research Institute (NHGRI). 2014. Jul. 17. http://www.genome.gov/10000207. Accessed 2014 Sep 30.
26 Giasuddin AS. Polymerase chain reaction technique: fundamental aspects and applications in clinical diagnostics. J Islam Acad Sci. 1995;8(1):29-32.
27 Henegariu O, Heerema NA, Dlouhy SR, et al. Multiplex PCR: critical parameters and step-by-step protocol. Biotechniques. Sep. 1997;23(3):504-11. [pmid: 9298224].
28 Real-Time qRT-PCR - Real-Time Quantitative Reverse Transcription PCR. Bethesda (MD). National Center for Biotechnology Information (NCBI). http://www.ncbi.nlm.nih.gov/projects/genome/probe/doc/TechQPCR.shtml. Accessed 2014 Oct 01.
29 Heid CA, Stevens J, Livak KJ, et al. Real time quantitative PCR. Genome Res. Oct. 1996;6(10):986-94. [pmid: 8908518].
30 Stuppia L, Antonucci I, Palka G, et al. Use of the MLPA Assay in the Molecular Diagnosis of Gene Copy Number Alterations in Human Genetic Diseases. Int J Mol Sci. 2012;13(3):3245-76. [pmid: 22489151].
31 MRC-Holland: multiplex ligation-dependent probe amplification (MLPA): copy number quantification and methylation detection [slide set]. Amsterdam (the Netherlands). MRC-Holland. 50 p. Also available: http://www.mlpa.com/WebForms/WebFormMain.aspx?Tag=_wl2zCji-rCGANQgZPuTixsEyIW1MscfzuKj2NDFYc-g.
32 Phillips T. The role of methylation in gene expression. Nat Educ. 2008;1(1):116.
33 Shen L, Waterland RA. Methods of DNA methylation analysis. Curr Opin Clin Nutr Metab Care. Sep. 2007;10:576-81. [pmid: 17693740].
34 Sun F, Bruening W, Erinoff E, et al. Addressing challenges in genetic test evaluation. Evaluation frameworks and assessment of analytic validity Methods research report. (Prepared by the ECRI Institute Evidence-based Practice Center under Contract No. HHSA 290-2007-10063-I.) AHRQ publication no. 11-EHC048-EF. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Jun. 2011:107. Also available: http://www.ncbi.nlm.nih.gov/books/NBK56750/pdf/TOC.pdf.