# Abbreviations and Acronyms

AAIDD: American Association on Intellectual and Developmental Disabilities
aCGH: microarray-based comparative genomic hybridization
AHRQ: Agency for Healthcare Research and Quality
ASD: autism spectrum disorder
AUC: area under the curve
CDC: Centers for Disease Control and Prevention
CGH: comparative genomic hybridization
CLIA: Clinical Laboratory Improvement Amendments of 1988
CMA: chromosomal microarray analysis
CNV: copy number variation
DD: developmental disability
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
FISH: fluorescence in situ hybridization
GDD: global developmental delay
GTR: Genetic Testing Registry
ID: intellectual disability
IQ: intelligence
KI: Key Informant
LDT: laboratory-developed test
MLPA: multiplex ligation-dependent probe amplification
NCBI: National Center for Biotechnology Information
NGS: next-generation sequencing
OMIM: Online Mendelian Inheritance in Man
PCR: polymerase chain reaction
PT: proficiency testing
RCT: randomized controlled trial
ROC: receiver operator characteristic
SNP: single nucleotide polymorphism
WES: whole exome sequencing
WGS: whole genome sequencing