# Excluded Studies Based on Review of Full-Length Articles

## Not a disorder of interest

Barcia G, Chemaly N, Gobin S, et al. Early epileptic encephalopathies associated with STXBP1 mutations: Could we better delineate the phenotype?. Eur J Med Genet. Jan. 2014;57(1):15-20. [pmid: 24189369].
Cody JD, Hasi M, Soileau B, et al. Establishing a reference group for distal 18q-: Clinical description and molecular basis. Hum Genet. Feb. 2014;133(2):199-209. [pmid: 24092497].
Del Giudice E, Macca M, Imperati F, et al. CNS involvement in OFD1 syndrome: a clinical, molecular, and neuroimaging study. Orphanet J Rare Dis. May. 10. 2014;9(1):74. [pmid: 24884629].

## Not a study design of interest

Carayol J, Tores F, Konig IR, et al. Evaluating diagnostic accuracy of genetic profiles in affected offspring families. Stat Med. Sep. 30. 2010;29(22):2359-68. [pmid: 20623818].

## Not a genetic test of interest

Mahajan S, Kaur A, Singh JR. Cytogenetic investigations in mentally challenged individuals. Int J Hum Genet. Jun. 2011;11(2):93-8.

## Not a US-based economic study

Regier DA, Friedman JM, Marra CA. Value for money? Array genomic hybridization for diagnostic testing for genetic causes of intellectual disability. Am J Hum Genet. May. 14. 2010;86(5):765-72. [pmid: 20398885].
Antonanzas F, RodriguezIbeas R, Hutter MF, et al. Genetic testing in the European Union: does economic evaluation matter?. Eur J Health Econ. Oct. 2012;13(5):651-61. http://dx.doi.org/10.1007/s10198-011-0319-x. [pmid: 21598012].

## A narrative review

Freitag CM, Staal W, Klauck SM, et al. Genetics of autistic disorders: review and clinical implications. Eur Child Adolesc Psychiatry. Mar. 2010;19(3):169-78. [pmid: 19941018].