# Ongoing Clinical Trials

Appendix E-1 Ongoing clinical trials

Identifier | Sponsor | Design | Purpose | Outcomes | Start Date and Expected Completion Date
Research and characterization of new genes involved in Intellectual Disability (GeneDefi) NCT01867554 | Institute National de la Sante Et of Medical Research, France | Prospective observational cohort study enrolling 2,500 patients with intellectual disability or psycho-motor retardation, 5,000 parents or unaffected siblings, and 1,000 affected siblings. Researchers will collect urine samples for processing. | To identify genes involved in intellectual disability with SNP-arrays, next generation sequencing and other newer methods and establish genotype-phenotype correlations. | Outcomes include the number of participants with a genetic cause identified and genotype-phenotype correlations over a 5-year followup period. | Start date: December 2012 End date: December 2022
Inter-regional project of the great western exploration approach for exome molecular causes severe intellectual disability isolated or syndromic (HUGODIMS) NCT02136849 | Nantes University Hospital, France | Prospective observational study of 225 patients with severe or moderate intellectual disability with isolated or syndromic presentation with negative fragile X and CGH results. | To evaluate high-throughput sequencing (NGS), to compare the exome of the child to the parent, and its contribution in the diagnostic management of patients with intellectual disability. | Outcomes to be assessed include the number of patients for whom de novo mutations are identified, the number of mutations compatible with the mode of recessive autosomal recessive or X-linked chromosome, and the number of de novo mutations (loss of function, missense, or indels) probably pathogens identified that are not known to be involved with the intellectual disability genes. | Start date: July 2014 Completion date: January 2017
The psychiatric and cognitive phenotypes in velocardiofacial syndrome, Williams syndrome, and fragile X syndrome characterization, treatment, and examining the connection to developmental and molecular factors NCT00768820 | Rabin Medical Center, Israel | Prospective interventional case series study of the efficacy and safety of methylphenidate, fluoxetine, and risperidone in 400 patients with a chromosomal deletion on FISH examination. | To investigate the psychiatric and cognitive phenotypes in velocardiofacial syndrome, Williams syndrome, and Fragile X syndrome, their response to treatment, and its relationship with molecular factors. | Outcomes to be assessed include psychological measures, molecular tests, and responsiveness to medical treatment at two years followup. | Start date: May 2001 Completion date: December 2012 Status is unknown; last NCT update was May 2012
Acquisition of saliva samples for validation as a specimen type in the Esoteric Genetic Laboratories fragile X assay NCT01616589 | Esoterix Genetic Laboratories, LLC, Burlington, NC, USA | Prospective cohort study of 100 patients previously identified as have fragile X intermediate, permutation (carrier) or full mutation (affected). | To determine whether saliva samples can be used as an alternative sample type to test for fragile X syndrome. | Outcome is fragile X diagnosis based on saliva sample. | Start date: not reported. Completion date: December 2012 Status unknown; last NCT update was June 2012
SynapDx autism spectrum disorder gene expression analysis study. NCT01810341 | SynapDx Corp., Lexington, MA, USA | Prospective observational cohort study of 880 patients between 18 and 60 months of age referred to a developmental evaluation center for evaluation of a possible developmental disorder. | To develop an algorithm to classify blood RNA gene expression patterns to maximize agreement between the classification and a clinical assessment of the presence or absence of autism spectrum disorder | Outcomes to be assessed include RNA expression in peripheral blood | Start date: March 2013 Completion date: September 2014 Study has been completed
Study of correlation between expression of proteins that are essential for embryonic brain development and neurodevelopmental outcomes at 2 years of age in premature infants. NCT01686685 | Hadassah Medical Organization, Israel | Prospective observational cohort study of 400 premature infants | Because premature birth is associated with an increased risk of autism, this study plans to measure changes in the expression of 3 different proteins that may be affected by changes in oxygen level at birth. Investigators will study the interaction between changes in protein levels in the first few days after premature birth and a diagnosis of ASD at 2 years of age. | Outcomes to be assessed include diagnoses of ASD at 2 years, and corrected age and language or cognitive delay at 2 years corrected age | Start date: April 2012 Completion date: not reported Status is unknown; last NCT update was September 2012
Exosomal MicroRNA expression in children with autism spectrum disorder. NCT01749670 | State University of New York – Upstate Medical Center, New York State, USA | Case-control study of 40 children. Cases include children 4–17 years of age with ASD versus age- and gender-matched controls with neuropsychological developmental patterns. | To identify small RNA particles that regulate gene expression in autism spectrum disorder and determine which miRNA patterns may improve our understanding and diagnosis of ASD. | The outcome to be assessed is the correlation between miRNA expression and medical/neuropsychological characteristics of study participants. | Start date: January 2013 Completion date: January 2014 Study has been completed
Early detection of autism spectrum disorder in children NCT01646866 | St. Louis University, St. Louis, Missouri, USA | Prospective observational cohort study of 50 biological siblings of a child with a diagnosis of ASD. The siblings will display red flags for autism through 1 year of age. | To identify infants at risk for autism less younger than 1 year of age to improve outcomes through early diagnosis and treatment. Correlation between clinical screening and genetic screening will be evaluated. | Outcomes to be assessed include the percentage of siblings with a high-risk genetic score on the ARISK genetic test who have a diagnosis of ASD at 24 months and the percentage of siblings who failed the Red Flags for Communication Scale at 12 months who have a diagnosis of ASD at 24 months | Start date: December 2010 Completion date: December 2016
Autism and glutamatergic synapse: Research of genetic mutations and identification of clinical and neurophysiological markers. NCT01770548 | University Hospital, Tours, France | Open-label, nonrandomized, parallel- assignment study enrolling 600 patients with a pervasive developmental disorder. Patients in the experimental arm will undergo an analysis of the glutamate synapse in autism, DNA will be collected, and auditory evoked potentials will be measured. | To analyze 50 genes in the glutamate synapse. | Outcomes to be assessed include an analysis of 50 genes encoding proteins of the NMDA receptor complex, chosen according to their chromosomal localization located in hotspots depicted by genome-wide screens in a large population of autistic children. | Start date: January 2009 Completion date: January 2011 Status unknown; last NCT update was January 2013
Use of pharmacogenetics in the treatment of children with ASD NCT00859664 | Assaf-Harofeh Medical Center, Israel | Prospective observational cohort study of 500 patients older than 3 years of age diagnosed with autism and treated with neuroleptics. | To map the different types of cytochrome P450 gene in children with autism to identify those for whom psychiatric drug treatment is successful and to prevent adverse drug reactions. | To evaluate the relationship between genotypes of the cytochrome P450 (CYP) 2D6 gene and response to treatment with psychiatric medications. | Start date: March 2009 Completion date: July 2011 Status unknown; last NCT update was March 2009

ASD=autism spectrum disorder; CGH=comparative genomic hybridization; FISH=fluorescent in situ hybridization; NCT=National Clinical Trials database; NGS=next-generation sequencing; SNP=single nucleotide polymorphism