# Genetic Tests for Developmental Disabilities

Table D-1 Genetic tests for Angelman syndrome

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000303241.5 | (AC) Atlanta Center: Medical Neurogenetics, LLC. Georgia 11D0703390 303241 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Skin\|White blood cell prep | Decline to answer | Yes
GTR000320684.3 | Ambry Genetics Ambry Genetics California 05D0981414 320684 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Cell culture\|Chorionic villi\|Dried blood spot (DBS) card\|Isolated DNA\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000512791.2 | Athena Diagnostics Inc Massachusetts 22D0069726 512791 | ARHGEF9\|ARX\|CDKL5\|CNTNAP2\|FOXG1\|GABRG2\|GRIN2A\|KCNT1\|MECP2\|NRXN1\|PCDH19\|PNKP\|RNASEH2A\|RNASEH2B\|RNASEH2C\|SAMHD1\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|STXBP1\|SYNGAP1\|TCF4\|TREX1\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000512796.2 | Athena Diagnostics Inc Massachusetts 22D0069726 512796 | ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATRX\|CACNA1A\|CASK\|CASR\|CCDC88C\|CDKL5\|CHRNA2\|CHRNA4\|CHRNB2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COL18A1\|COL4A1\|CPT2\|CSTB\|CTSD\|CUL4B\|DCX\|DEPDC5\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FGD1\|FGFR3\|FKRP\|FKTN\|FLNA\|FOXG1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GPC3\|GPR56\|GRIA3\|GRIN2A\|HSD17B10\|KCNA1\|KCNJ1\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|LAMA2\|LARGE\|LBR\|LGI1\|MBD5\|ME2\|MECP2\|MEF2C\|MFSD8\|NHLRC1\|NIPBL\|NOTCH3\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PCDH19\|PEX7\|PHF6\|PIGV\|PLA2G6\|PLP1\|PNKP\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRRT2\|RAB39B\|RAB3GAP1\|RAI1\|RELN\|RNASEH2A\|RNASEH2B\|RNASEH2C\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SERPINI1\|SETBP1\|SLC25A22\|SLC2A1\|SLC4A10\|SLC9A6\|SMC1A\|SMC3\|SMS\|SNAP29\|SPTAN1\|SRPX2\|STXBP1\|SYNGAP1\|SYP\|TBC1D24\|TBX1\|TCF4\|TPP1\|TREX1\|TSC1\|TSC2\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VPS13A\|VPS13B\|WDR62\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000335343.1 | BayCare Cytogenetics Laboratory BayCare Laboratories, LLC Florida 10D2029560 335343 | UBE3A | FISH-metaphase | Digital/Virtual karyotyping | Peripheral (whole) blood | Decline to answer | Yes
GTR000505711.2 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 505711 | UBE3A | Methylation analysis | PCR-RFLP with Southern hybridization | Peripheral (whole) blood | No | No
GTR000508280.2 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 508280 | AARS2\|AASS\|ABAT\|ABCA12\|ABCA4\|ABCB11\|ABCB4\|ABCB6\|ABCB7\|ABCD1\|ABHD12\|ABHD5\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACO2\|ACOX1\|ACSF3\|ACSL4\|ADAM9\|ADCK3\|ADSL\|AFG3L2\|AGK\|AGL\|AGPS\|AGXT\|AIFM1\|AIPL1\|AK1\|AK2\|AKAP10\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|ALDOA\|ALDOB\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ALMS1\|AMACR\|AMER1\|AMN\|AMT\|ANKH\|ANKRD26\|AP3B1\|APP\|APTX\|ARG1\|ARL6\|ASL\|ASS1\|ATIC\|ATP5E\|ATP6V0A2\|ATP7A\|ATP7B\|ATP8B1\|ATPAF2\|AUH\|B4GALT1\|B4GALT7\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BCKDHA\|BCKDHB\|BCOR\|BCS1L\|BEST1\|BLOC1S3\|BOLA3\|BRCA1\|BTD\|C10orf2\|C12orf65\|C1QTNF5\|C2orf71\|C8orf37\|CA2\|CA4\|CABP4\|CACNA1F\|CACNA2D4\|CASP8\|CAT\|CBS\|CC2D2A\|CCDC28B\|CCDC39\|CDH23\|CDHR1\|CEP290\|CERKL\|CHAT\|CHM\|CISD2\|CLCN7\|CLN3\|CLRN1\|CNGA1\|CNGA3\|CNGB1\|CNGB3\|COG1\|COG7\|COG8\|COL1A1\|COL1A2\|COL2A1\|COL3A1\|COL5A1\|COL5A2\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|CPOX\|CPS1\|CPT1A\|CPT2\|CRB1\|CRTAP\|CRX\|CRYAB\|CTSA\|CTSD\|CTSK\|CUBN\|CYB5A\|CYB5R3\|CYBA\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP17A1\|CYP1B1\|CYP24A1\|CYP27A1\|CYP27B1\|CYP4V2\|D2HGDH\|DARS2\|DBT\|DDOST\|DFNB31\|DGUOK\|DHDDS\|DHODH\|DIABLO\|DLAT\|DLD\|DMGDH\|DNAJC19\|DNM1L\|DPM1\|DPM3\|DSP\|DTNBP1\|EFEMP1\|ELAC2\|ELN\|ELOVL4\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|EYA1\|EYA4\|EYS\|FAH\|FAM161A\|FAM20C\|FASTKD2\|FBLN5\|FBN1\|FBP1\|FECH\|FH\|FKBP10\|FLVCR1\|FOXC1\|FOXL2\|FOXRED1\|FRMD7\|FSCN2\|FXN\|FYCO1\|FZD4\|G6PC\|GAA\|GAD1\|GALC\|GALE\|GALK1\|GALNS\|GALT\|GAMT\|GARS\|GATM\|GBE1\|GCDH\|GCK\|GCKR\|GCSH\|GFER\|GFM1\|GIF\|GJA3\|GK\|GLB1\|GLDC\|GLRX5\|GLUD1\|GLYCTK\|GM2A\|GNAT1\|GNAT2\|GNE\|GNPTAB\|GNS\|GOT1\|GPD1\|GPD2\|GPI\|GPR143\|GPR98\|GPX1\|GRK1\|GRM6\|GRN\|GSN\|GUCA1A\|GUCA1B\|GUCY2D\|GUSB\|GYS1\|GYS2\|HADHA\|HADHB\|HAGH\|HARS\|HAX1\|HBB\|HCCS\|HESX1\|HEXA\|HEXB\|HGSNAT\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HNF1A\|HNF1B\|HP\|HPRT1\|HPS1\|HPS3\|HPS4\|HPS5\|HPS6\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH2\|IDH3B\|IMPDH1\|IMPG2\|INPP5E\|INVS\|IQCB1\|ISCU\|IVD\|JAG1\|KARS\|KCNJ13\|KCNV2\|KIF1B\|KIF21A\|KLHL7\|KRT12\|KRT3\|KRT5\|L2HGDH\|LCA5\|LDHA\|LDHB\|LEMD3\|LEPRE1\|LIAS\|LMBRD1\|LMX1B\|LPIN1\|LRAT\|LRP5\|LRPPRC\|MAN2B1\|MANBA\|MAOA\|MC1R\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MEF2A\|MEN1\|MERTK\|MFN2\|MFRP\|MGAT2\|MKKS\|MKS1\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MPDU1\|MPI\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MSRB3\|MTHFR\|MTO1\|MTPAP\|MTR\|MTRR\|MUT\|MUTYH\|MYO7A\|MYOC\|NAGLU\|NAGS\|NCOA4\|NDP\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NEFH\|NEUROD1\|NFU1\|NHS\|NME1\|NPHP1\|NPHP3\|NPHP4\|NRL\|NT5C3A\|NUBPL\|NYX\|OAT\|OCA2\|OCRL\|OGDH\|OGG1\|OPA1\|OPA3\|OPN1LW\|OPN1MW\|OPTN\|OSTM1\|OTC\|OTX2\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PAX2\|PAX6\|PC\|PCCA\|PCCB\|PCDH15\|PCK2\|PDE6A\|PDE6B\|PDE6C\|PDE6G\|PDHA1\|PDHB\|PDP1\|PDSS1\|PDSS2\|PDZD7\|PFKM\|PGAM2\|PGM1\|PHB\|PHKA1\|PHKA2\|PHKB\|PHKG2\|PHOX2A\|PHYH\|PINK1\|PITPNM3\|PITX2\|PITX3\|PLA2G2A\|PLOD2\|PLOD3\|PMM2\|PNKD\|PNPLA2\|POLG\|POLG2\|PPARG\|PPARGC1B\|PPIB\|PPOX\|PPP2R1B\|PRCD\|PRKCG\|PRODH\|PROM1\|PRPF31\|PRPF6\|PRPF8\|PRPH2\|PSAP\|PSEN1\|PTRF\|PTS\|PUS1\|PYCR1\|PYGL\|PYGM\|QDPR\|RAF1\|RARS2\|RAX\|RB1\|RD3\|RDH12\|RDH5\|REEP1\|RET\|RFT1\|RGR\|RGS9\|RHO\|RILP\|RIMS1\|RLBP1\|RNASEL\|RP1\|RP1L1\|RP2\|RP9\|RPE65\|RPGR\|RPGRIP1\|RPL35A\|RPS14\|RRM2B\|RS1\|SAG\|SARDH\|SARS2\|SCO2\|SCP2\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SECISBP2\|SEMA4A\|SEPT9\|SERPINF1\|SGSH\|SHH\|SIX6\|SLC16A1\|SLC22A4\|SLC22A5\|SLC24A1\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC26A4\|SLC34A1\|SLC35A1\|SLC35C1\|SLC37A4\|SLC39A13\|SLC3A1\|SLC45A2\|SLC9A3R1\|SLC9A6\|SMPD1\|SNCB\|SNRNP200\|SOD1\|SOD2\|SOST\|SOX2\|SP7\|SPATA7\|SPG7\|SPR\|SPTLC2\|SQSTM1\|SRD5A3\|STAR\|STAT1\|STAT3\|STRA6\|STXBP1\|SUCLA2\|SUCLG1\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TCN2\|TEAD1\|TGFB1\|TGFBI\|TIMM8A\|TIMP3\|TK2\|TLR3\|TLR4\|TMEM126A\|TMEM127\|TMEM67\|TMEM70\|TNFRSF11A\|TNFRSF11B\|TNFSF11\|TOPORS\|TP53\|TPP1\|TRIM32\|TRMU\|TRPM1\|TSFM\|TSPAN12\|TTC19\|TTC8\|TUBA1A\|TUBB3\|TUFM\|TULP1\|TUSC3\|TYMP\|TYR\|TYROBP\|TYRP1\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|USH1C\|USH1G\|USH2A\|VCP\|VHL\|VSX1\|WFS1\|WT1\|WWOX\|XDH\|XPNPEP3\|YARS2\|ZEB1\|ZFHX3\|ZNF513 | Deletion/duplication analysis | Comparative Genomic Hybridization | NR | NR | NR
GTR000512051.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512051 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512052.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512052 | MECP2 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | NR | NR | No
GTR000512053.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512053 | MECP2 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | NR | NR | No
GTR000512054.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512054 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512055.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512055 | MECP2 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512056.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512056 | MECP2 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512174.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512174 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512175.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512175 | UBE3A | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512176.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512176 | UBE3A | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000006790.1 | Center for Human Genetics Laboratory University Hospitals - University Hospitals Laboratory Service Foundation Ohio 36D0656024 6790 | 15q11.2 | FISH-metaphase\|Methylation analysis\|Uniparental disomy study (UPD) | Other\|Methylation-specific PCR\|Other | Amniocytes\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000206881.1 | Center for Human Genetics, Inc Massachusetts 22D0650242 206881 | 15q11-q13 | FISH-metaphase\|Methylation analysis\|Sequence analysis of the entire coding region\|Uniparental disomy study (UPD) | Fluorescence in situ Hybridization (FISH)\|Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis\|PCR on ABI | NR | Decline to answer | No
GTR000196491.3 | ChildLab Molecular Genetics Laboratory Nationwide Children’s Hospital Ohio 36D0665271 196491 | 15q11.2-q13 | FISH-metaphase\|Methylation analysis\|Sequence analysis of the entire coding region\|Uniparental disomy study (UPD) | FISH for 15q11.2 deletion\|Methylation-specific PCR\|Bi-directional Sanger Sequence Analysis\|characterization of microsatellite polymorphisms on ABI instrument | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000295235.1 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 295235 | 15q11-q13 | FISH-metaphase | Metaphase FISH analysis | Amniocytes\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000005568.2 | Clinical Molecular Genetics Laboratory All Children’s Hospital Florida 10D0700790 5568 | 15q11-q13 | Methylation analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Buccal swab\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000500883.8 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500883 | ABAT\|ABCC2\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|AKT3\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASAH1\|ASPA\|ASPM\|ATIC\|ATN1\|ATP1A2\|ATP1A3\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BRAF\|BRAT1\|BRD2\|BTD\|BUB1B\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT1A\|CPT2\|CSTB\|CTSA\|CTSD\|CTSF\|CUL4B\|CYP1B1\|CYP2A6\|CYP2B6\|CYP2C19\|CYP2C9\|CYP2D6\|CYP2R1\|CYP2U1\|CYP3A5\|DBT\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FAAH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FOXH1\|FUCA1\|GABBR2\|GABRA1\|GABRA2\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDH2\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIAS\|LIG4\|LRPPRC\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED12\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NGLY1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPA1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PIK3CA\|PIK3R2\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|RTTN\|SAMHD1\|SCARB2\|SCN10A\|SCN11A\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGCE\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SNIP1\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|ST3GAL5\|STIL\|STRADA\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TRPM6\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | No
GTR000500936.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500936 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|C21orf33\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|G6PD\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|HTT\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000503671.2 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 503671 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000510912.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 510912 | ADSL\|ALDH7A1\|ARHGEF9\|ARX\|ATP6AP2\|CACNB4\|CDKL5\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CSTB\|CTSD\|EFHC1\|EPM2A\|FOLR1\|FOXG1\|GABRA1\|GABRG2\|GAMT\|GATM\|GOSR2\|GRIN2A\|KANSL1\|KCNJ10\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|LGI1\|LIAS\|MAGI2\|MBD5\|MECP2\|MEF2C\|MFSD8\|NHLRC1\|NRXN1\|PCDH19\|PLCB1\|PNKP\|PNPO\|POLG\|PPT1\|PRICKLE1\|PRRT2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|STXBP1\|SYN1\|SYNGAP1\|TBC1D24\|TCF4\|TPP1\|TSC1\|TSC2\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fetal blood\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000327615.1 | Cytogenetics and Molecular Diagnostics Lab CGC Genetics USA New Jersey 31D1085261 327615 | SNRPN\|UBE3A, 15q11.2 | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis\|Methylation analysis\|Sequence analysis of the entire coding region | FISH\|FISH\|Multiplex Ligation-dependent Probe Amplification (MLPA)\|Methylation-specific PCR\|Uni-directional Sanger sequencing | Cell-free DNA\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000325589.3 | Cytogenetics and Molecular Genetics Laboratory Mercy St. Vincent Medical Center Ohio 36D0965797 325589 | 15q11.2 | FISH-metaphase\|Methylation analysis | FISH\|Methylation-specific PCR | Peripheral (whole) blood | Decline to answer | Yes
GTR000013524.1 | Cytogenetics Laboratory Indiana University School of Medicine Indiana 15D0647198 13524 | 15q11.2-q13 | FISH-interphase\|FISH-metaphase | Fluorescence in situ hybridization (FISH)\|Fluorescence in situ hybridization (FISH) | Amniocytes\|Amniotic fluid\|Bone marrow\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin\|Urine | Decline to answer | Yes
GTR000032601.1 | Cytogenetics Laboratory SUNY Upstate Medical University New York 33D0654590 32601 | 15q11.2-q13 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Cord blood\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Yes | Yes
GTR000500042.2 | Cytogenetics Laboratory ARUP Laboratories, Inc. Utah 46D0523979 500042 | 15q11.2-q13\|17p11.2\|17p13.3\|22q11.2\|22q13.3\|4p16.3\|5p15.2\|7q11.23\|Xp22.3\|Yp11.3 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000501320.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501320 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | No | No
GTR000501321.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501321 | UBE3A | Deletion/duplication analysis | Comparative Genomic Hybridization | NR | No | No
GTR000512416.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512416 | ABAT\|ADSL\|ALDH7A1\|ARHGEF9\|ARX\|ASPM\|ATP1A2\|ATP6AP2\|BCKDK\|CACNA1A\|CACNB4\|CASK\|CASR\|CDKL5\|CENPJ\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CPA6\|CSTB\|CTSD\|DCX\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FLNA\|FOLR1\|FOXG1\|GABRA1\|GABRG2\|GAMT\|GATM\|GOSR2\|GPR56\|GPR98\|GRIN2A\|HCN1\|HCN4\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|LGI1\|LIAS\|MAGI2\|MBD5\|MCPH1\|MECP2\|MEF2C\|MFSD8\|MTHFR\|NDE1\|NDUFA1\|NHLRC1\|NRXN1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PLCB1\|PNKP\|PNPO\|POLG\|PPT1\|PRICKLE1\|PRICKLE2\|PRRT2\|RELN\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN3A\|SCN8A\|SCN9A\|SHH\|SIX3\|SLC19A3\|SLC25A19\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|SRPX2\|ST3GAL3\|ST3GAL5\|STIL\|STXBP1\|SYN1\|TBC1D24\|TCF4\|TPP1\|TSC1\|TSC2\|TSEN54\|UBE3A\|WDR62\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512586.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512586 | ABCD1\|ACSL4\|AFF2\|AP1S2\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDK16\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|HCCS\|HCFC1\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|KLF8\|L1CAM\|LAMP2\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SYN1\|SYP\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|ZDHHC15\|ZDHHC9\|ZNF711 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512587.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512587 | ADSL\|AFF2\|AP1S2\|ARX\|ATRX\|BCKDK\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DHCR7\|DMD\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|HPRT1\|KDM5C\|L1CAM\|MAGEL2\|MBD5\|MECP2\|MED12\|MEF2C\|MID1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NR1I3\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RELN\|SCN1A\|SLC2A1\|SLC9A6\|SMARCB1\|SMC1A\|TCF4\|UBE2A\|UBE3A\|VPS13B\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512608.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512608 | ACTB\|ACTG1\|ADSL\|AHI1\|ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ASPM\|ATP1A2\|ATP6AP2\|ATR\|ATRX\|BCKDK\|CACNB4\|CASC5\|CASK\|CC2D2A\|CDC6\|CDK5RAP2\|CDKL5\|CDT1\|CENPJ\|CEP135\|CEP152\|CEP290\|CEP41\|CEP63\|CHMP1A\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CPA6\|CSTB\|CTSD\|DCX\|DHCR7\|DISP1\|DNAJC5\|EFHC1\|EHMT1\|EOMES\|EPM2A\|EXOSC3\|FGF8\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FOXH1\|GABRA1\|GABRG2\|GAMT\|GATM\|GLI2\|GOSR2\|GPR56\|GPR98\|GRIN2A\|GRIN2B\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KIAA1279\|KIF7\|LAMC3\|LARGE\|LARP7\|LGI1\|LIAS\|MAGI2\|MAPK10\|MBD5\|MCPH1\|MECP2\|MEF2C\|MFSD8\|MKS1\|MYCN\|NDE1\|NHLRC1\|NIN\|NODAL\|NPHP1\|NRXN1\|OPHN1\|ORC4\|ORC6\|PAFAH1B1\|PCDH19\|PCNT\|PLCB1\|PNKP\|PNPO\|POC1A\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRRT2\|PTCH1\|RAB18\|RAB3GAP1\|RAB3GAP2\|RARS2\|RBBP8\|RELN\|RPGRIP1L\|RTTN\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SHH\|SIX3\|SLC19A3\|SLC25A19\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|SRPX2\|ST3GAL3\|ST3GAL5\|STIL\|STXBP1\|SYN1\|TBC1D24\|TCF4\|TGIF1\|TMEM138\|TMEM216\|TMEM237\|TMEM67\|TPP1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|UBE3A\|VLDLR\|VRK1\|WDR62\|ZEB2\|ZIC2\|ZNF335 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000509342.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509342 | ANKRD11\|AP1S2\|ARX\|ATRX\|AUTS2\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CHD8\|CNTNAP2\|CNTNAP5\|CREBBP\|DHCR7\|DLGAP2\|DMD\|DOCK4\|DPP10\|DPP6\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GABRG1\|GNA14\|GRIN2B\|GRPR\|HOXA1\|HPRT1\|IMMP2L\|KATNAL2\|KCTD13\|KDM5C\|KIRREL3\|KLHL3\|L1CAM\|LAMC3\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|NEGR1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRXN1\|NSD1\|NTNG1\|OPHN1\|PAFAH1B1\|PCDH19\|PCDH9\|PDE10A\|PHF6\|PIP5K1B\|PNKP\|PON3\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RBFOX1\|RELN\|RPL10\|SATB2\|SCN1A\|SCN2A\|SHANK2\|SHANK3\|SLC6A4\|SLC9A6\|SLC9A9\|SMC1A\|SMG6\|SNRPN\|SOX5\|SPAST\|ST7\|STK3\|TCF4\|TSC1\|TSC2\|UBE3A\|VPS13B\|ZEB2\|ZNF507\|ZNF804A\|ZNHIT6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509399.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509399 | ABAT\|ABCB1\|ABCC8\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCS1L\|BRAF\|BTD\|BUB1B\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COG1\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|EFHC1\|EFHC2\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HCN1\|HCN4\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|IDS\|IDUA\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIG4\|LRPPRC\|MAGI2\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MLC1\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDSS1\|PDSS2\|PEX1\|PEX12\|PEX14\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PHF6\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN10A\|SCN1A\|SCN1B\|SCN2A\|SCN2B\|SCN3A\|SCN3B\|SCN4A\|SCN4B\|SCN5A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC17A5\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35C1\|SLC46A1\|SLC6A5\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRPX2\|STIL\|STXBP1\|SUMF1\|SUOX\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509436.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509436 | ABCC8\|ACY1\|ADAMTSL2\|ADSL\|AGA\|ALDH4A1\|ALDH5A1\|ALDH7A1\|AMT\|ANTXR2\|ARG1\|ARSA\|ARSB\|ASAH1\|ASPA\|ATP13A2\|BTD\|CLN3\|CLN5\|CLN6\|CLN8\|COL11A2\|COL2A1\|CTNS\|CTSA\|CTSC\|CTSD\|CTSK\|DHCR7\|DNAJC5\|DPYD\|DYM\|ETFA\|ETFB\|ETFDH\|FH\|FOLR1\|FUCA1\|GAA\|GALC\|GALNS\|GAMT\|GBA\|GCDH\|GCSH\|GLA\|GLB1\|GLDC\|GM2A\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GUSB\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|IDS\|IDUA\|L2HGDH\|LAMA2\|LAMP2\|LIPA\|LMBRD1\|MAN2B1\|MANBA\|MCOLN1\|MFSD8\|MOCS1\|MOCS2\|NAGA\|NAGLU\|NEU1\|NPC1\|NPC2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX26\|PEX3\|PEX5\|PEX6\|PGK1\|PHYH\|PPT1\|PRODH\|PSAP\|QDPR\|RAI1\|SGSH\|SLC17A5\|SLC25A15\|SLC46A1\|SMPD1\|SUMF1\|SUOX\|TCF4\|TPP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509442.11 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509442 | ABCC6\|ABCD1\|ABCG5\|ACAT1\|ACOX1\|ACSL4\|ACY1\|ADAR\|ADSL\|AFF2\|AFP\|AGL\|AGT\|AGTR2\|AHI1\|AIFM1\|ALDH18A1\|ALDH4A1\|ALG11\|ALG12\|ALG6\|ALX4\|AMER1\|AP1S1\|AP1S2\|AP3B1\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|APOB\|AQP7\|AR\|ARG1\|ARHGEF6\|ARID1A\|ARID1B\|ARX\|ASPM\|ASS1\|ATL1\|ATM\|ATP13A2\|ATP1A2\|ATP6AP2\|ATP7A\|ATRX\|AUH\|AVP\|AVPR2\|BBS9\|BCS1L\|BIN1\|BRCA2\|BRIP1\|BRWD3\|BUB1B\|CACNG2\|CAMTA1\|CANT1\|CASK\|CBS\|CC2D1A\|CC2D2A\|CCDC88C\|CDH15\|CDKL5\|CDKN1C\|CEP290\|CEP41\|CEP57\|CHD7\|CHRNA4\|CLN3\|CNTNAP2\|COG5\|COG7\|COL1A2\|CP\|CPA6\|CPS1\|CRADD\|CRBN\|CTC1\|CTNNB1\|CTSA\|CUL4B\|CYB5R3\|CYP27A1\|D2HGDH\|DARS2\|DBT\|DHCR24\|DHCR7\|DIP2B\|DLG3\|DMD\|DPYD\|DYNC1H1\|DYRK1A\|EBP\|EFNB1\|EHMT1\|ELOVL4\|ERCC2\|ERCC3\|ERCC5\|ERCC6\|ERCC8\|F5\|FAM126A\|FANCG\|FBLN5\|FBN1\|FBN2\|FGD1\|FGF14\|FGFR1\|FGFR2\|FGFR3\|FKRP\|FKTN\|FMR1\|FOXG1\|FOXP1\|FTO\|FTSJ1\|G6PC3\|GABRG2\|GALE\|GAMT\|GAN\|GBA\|GBE1\|GCK\|GDI1\|GFAP\|GFM1\|GHR\|GLI3\|GLRA1\|GLUL\|GLYCTK\|GM2A\|GNAS\|GNPAT\|GNPTAB\|GNPTG\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|GRM1\|GSS\|GUSB\|GYS2\|HAX1\|HDAC4\|HDAC8\|HEPACAM\|HEXB\|HOXD10\|HPD\|HSD17B10\|HSPD1\|HUWE1\|IDS\|IGBP1\|IGF1\|IGF1R\|IL1RAPL1\|INSR\|IQSEC2\|IRX5\|ITGA7\|KCNJ10\|KCNJ11\|KCNK9\|KCNQ2\|KCTD7\|KDM5C\|KIF11\|KIF1A\|KIF21A\|KIF5A\|KIF7\|KIRREL3\|KRAS\|L1CAM\|LAMA2\|LAMP2\|LARGE\|LBR\|LHX3\|LIG4\|LMBRD1\|LRP5\|LYST\|MAGT1\|MAN1B1\|MAN2B1\|MANBA\|MAPT\|MAT1A\|MBD5\|MBTPS2\|MCCC1\|MCCC2\|MCOLN1\|MCPH1\|MECP2\|MED17\|MED23\|MEF2C\|MFSD8\|MGAT2\|MKKS\|MMADHC\|MOCS2\|MPI\|MPZ\|MRAP\|MTFMT\|MTHFR\|MTR\|MYCN\|MYO5A\|MYO7A\|NAGA\|NBN\|NDP\|NDUFA1\|NDUFAF5\|NDUFS1\|NF1\|NGF\|NHEJ1\|NHP2\|NIPBL\|NLGN3\|NPC1\|NPC2\|NPHP3\|NRXN1\|NSDHL\|NSUN2\|OFD1\|OPHN1\|ORC1\|PAFAH1B1\|PAH\|PAK3\|PAX6\|PCDH19\|PCNT\|PDE4D\|PDHX\|PDSS1\|PEX7\|PGK1\|PHF8\|PHKA2\|PHKG2\|PIGL\|PIGO\|PIGV\|PLA2G6\|PLP1\|POMGNT1\|POMT1\|POMT2\|POU1F1\|PPOX\|PQBP1\|PRICKLE1\|PRKAR1A\|PRSS12\|PTEN\|PTPN11\|PYCR1\|PYGL\|RAB39B\|RAB40AL\|RAI1\|RAPSN\|RBBP8\|RBM10\|RFX6\|RPGRIP1L\|RPS6KA3\|SACS\|SAMHD1\|SATB2\|SCN1A\|SCN8A\|SDCCAG8\|SGCA\|SGSH\|SHANK2\|SHANK3\|SHROOM4\|SIL1\|SLC16A2\|SLC20A2\|SLC25A12\|SLC25A13\|SLC25A15\|SLC2A1\|SLC2A2\|SLC35C1\|SLC46A1\|SLC4A4\|SLC5A2\|SLC5A5\|SLC6A4\|SLC6A8\|SLC7A7\|SLC9A6\|SLX4\|SMARCA4\|SMARCB1\|SMC1A\|SMS\|SNIP1\|SOBP\|SOX10\|SOX2\|SOX3\|SPR\|SPTAN1\|SPTLC1\|SRD5A3\|SRPX2\|ST3GAL3\|STAT5B\|STRA6\|STX11\|STXBP1\|SUCLG1\|SYNGAP1\|SYP\|SYT14\|TBC1D24\|TBCE\|TBX1\|TECR\|TGIF1\|TH\|THRB\|TINF2\|TMCO1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPH2\|TPK1\|TRAPPC9\|TRHR\|TSC1\|TSC2\|TSHR\|TSPAN7\|TTC37\|TTR\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|TUSC3\|TWIST1\|UBE2A\|UBE3A\|UPB1\|UPF3B\|UROC1\|USP9X\|VLDLR\|VPS13B\|WDR62\|WDR81\|WRN\|XIST\|XPNPEP3\|ZBTB16\|ZBTB24\|ZDHHC9\|ZEB2\|ZFP57\|ZFYVE26\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | NR | NR
GTR000509443.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509443 | ALDH7A1\|ARX\|ATP1A2\|CACNA1A\|CDKL5\|FOLR1\|FOXG1\|GAMT\|KCNQ2\|MECP2\|PCDH19\|PHGDH\|PNPO\|POLG\|PPT1\|SCN1A\|SLC2A1\|STXBP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509462.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509462 | ARX\|ATRX\|CAV1\|CDKL5\|CNTNAP2\|FOXG1\|MECP2\|MED17\|MEF2C\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|TRAPPC9\|UBE3A\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510915.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510915 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ABCD3\|ACACA\|ACACB\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACLY\|ACO2\|ACSF3\|ACSL4\|ACSL5\|ACSM3\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AGXT2\|AIFM1\|AK2\|AKAP10\|AKR7A2\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|AS3MT\|ASS1\|ATIC\|ATP10D\|ATP5E\|ATP5SL\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BAX\|BCAT1\|BCAT2\|BCKDHA\|BCKDHB\|BCL2\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDC42BPB\|CDKL5\|CFTR\|CHAT\|CHDH\|CHRNA4\|CHRNB2\|CISD2\|CKM\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CLYBL\|CNR1\|COA5\|COMT\|COQ2\|COQ4\|COQ5\|COQ6\|COQ9\|COX10\|COX15\|COX4I1\|COX4I2\|COX6B1\|COX7A2\|CPOX\|CPS1\|CPT1A\|CPT1B\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDAH1\|DDC\|DECR1\|DGUOK\|DHODH\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNAJC5\|DNM1L\|DTNBP1\|EARS2\|ECI1\|ECSIT\|ELAC2\|ELN\|ENO1\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FAAH\|FARS2\|FASN\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FPGS\|FTH1\|FXN\|G6PC\|G6PD\|GAD1\|GAD2\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLO1\|GLRA1\|GLRX5\|GLS\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPAM\|GPD1\|GPD2\|GPI\|GPX1\|GPX4\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HARS\|HARS2\|HCCS\|HIBCH\|HIGD2A\|HK1\|HK2\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B1\|HSD3B2\|HSPA9\|HSPB7\|HSPD1\|HTRA2\|HTT\|IDE\|IDH1\|IDH2\|IDH3B\|IMMP2L\|IMMT\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|KYNU\|L2HGDH\|LARS2\|LDHA\|LDHB\|LETM1\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MAOB\|MARS2\|MAVS\|MCCC1\|MCCC2\|MCEE\|MDH1\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MGLL\|MGST3\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCOS\|MOCS1\|MOCS2\|MOGS\|MRPL3\|MRPL48\|MRPS16\|MRPS22\|MRRF\|MTCH2\|MTFMT\|MTHFD1\|MTHFD1L\|MTHFS\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA4\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB1\|NDUFB3\|NDUFB6\|NDUFB9\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NFU1\|NIPSNAP1\|NIPSNAP3A\|NLRX1\|NME1\|NOS3\|NPL\|NRXN1\|NTHL1\|NUBPL\|OAT\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PACRG\|PAH\|PAK7\|PANK2\|PARK2\|PARL\|PARP1\|PC\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PKLR\|PMPCA\|PNKD\|PNMT\|POLG\|POLG2\|POLRMT\|PPARGC1A\|PPARGC1B\|PPOX\|PPT1\|PREPL\|PRODH\|PTGES2\|PTS\|PUS1\|PYCR1\|QDPR\|RAB11FIP5\|RARS2\|REEP1\|RNASEL\|RPL35A\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SHMT1\|SIRT1\|SIRT3\|SIRT5\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A39\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|TACO1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TFAM\|TFB1M\|TIMM44\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOMM40\|TOP1MT\|TP53\|TPH2\|TPI1\|TPP1\|TRMU\|TSFM\|TSPO\|TST\|TTC19\|TUFM\|TXN2\|TXNRD2\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|USP24\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510916.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510916 | ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|AP1S2\|ARHGEF6\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|EBP\|FAAH2\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|GSPT2\|HCCS\|HDAC8\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|L1CAM\|LAMP2\|MAGT1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RAB40AL\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SRPX2\|SYN1\|SYP\|TAF1\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|USP9X\|WDR13\|ZCCHC12\|ZDHHC15\|ZDHHC9\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000006812.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 6812 | 15q11.2-q13 | Methylation analysis | Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000006814.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 6814 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500120.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500120 | UBE3A | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500149.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500149 | 15q11-q13 | Uniparental disomy study (UPD) | Microsatellite analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500158.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500158 | MECP2\|SLC9A6\|TCF4\|UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500159.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500159 | 15q11-q13 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000501098.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 501098 | ARX\|ATRX\|CDKL5\|CNTNAP2\|DYRK1A\|EHMT1\|FOLR1\|FOXG1\|MBD5\|MECP2\|MEF2C\|NRXN1\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|UBE3A\|ZEB2 | Deletion/duplication analysis | Comparative Genomic Hybridization | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000501110.4 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 501110 | ARX\|ATRX\|CDKL5\|CNTNAP2\|DYRK1A\|EHMT1\|FOLR1\|FOXG1\|MBD5\|MECP2\|MEF2C\|NRXN1\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000507771.3 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 507771 | ARFGEF2\|ASPM\|ATR\|ATRX\|CASC5\|CASK\|CDC6\|CDK5RAP2\|CDKL5\|CDT1\|CENPJ\|CEP135\|CEP152\|CEP63\|FOXG1\|MCPH1\|MECP2\|MED17\|NDE1\|ORC1\|ORC4\|ORC6\|PCNT\|PNKP\|RAB3GAP1\|RBBP8\|SLC25A19\|SLC2A1\|SLC9A6\|STAMBP\|STIL\|TCF4\|TSEN2\|TSEN34\|TSEN54\|UBE3A\|WDR62\|ZEB2\|ZNF335 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000226643.3 | Genetics Laboratory University of Oklahoma Health Sciences Center Oklahoma 37D0967945 226643 | UBE3A | FISH-metaphase\|Methylation analysis\|Sequence analysis of the entire coding region | G-banding\|Methylation-specific PCR\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000204024.1 | Greenwood Genetic Center Diagnostic Laboratories Greenwood Genetic Center South Carolina 42D0689473 204024 | SNRPN\|UBE3A, Chromosome 15 | Methylation analysis\|Sequence analysis of the entire coding region\|Uniparental disomy study (UPD) | Pyrosequencing\|Bi-directional Sanger Sequence Analysis\|Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Saliva\|Skin | Decline to answer | Yes
GTR000053112.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 53112 | 15q11-q13 | FISH-interphase\|FISH-metaphase\|Methylation analysis\|Sequence analysis of the entire coding region | Other\|Other\|Methylation-specific PCR\|Methylation-specific PCR | Fetal blood\|Peripheral (whole) blood | No | Yes
GTR000327662.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 327662 | AP1S2\|ARX\|ASPM\|ATRX\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CBL\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DCX\|DHCR7\|DMD\|EHMT1\|ERCC6\|ERCC8\|FGD1\|FGFR1\|FGFR2\|FGFR3\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|HDAC8\|HOXA1\|HPRT1\|HRAS\|KDM5C\|KMT2D\|KRAS\|L1CAM\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|MKKS\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCH1\|PTEN\|PTPN11\|RAB39B\|RAD21\|RAF1\|RAI1\|RELN\|RPGRIP1L\|RPS6KA3\|SCN1A\|SHANK2\|SHANK3\|SHOC2\|SLC2A1\|SLC6A4\|SLC9A6\|SMC1A\|SMC3\|SOS1\|SPRED1\|TCF4\|TSC1\|TSC2\|TUBA1A\|UBE3A\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | No | No
GTR000331374.1 | Knight Diagnostic Laboratories - Molecular Diagnostic Center Oregon Health and Science University Oregon 38D0881787 331374 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000500958.4 | Mayo Clinic Genetic Testing Laboratories Mayo Clinic Minnesota 24D0404292 500958 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniotic fluid\|Chorionic villi\|Peripheral (whole) blood | No | Yes
GTR000509438.3 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 509438 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000500632.3 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500632 | 15q11.2 | Fluorescence in situ hybridization (FISH) | Other | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Dried blood spot (DBS) card\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC) | No | Yes
GTR000084937.2 | Molecular Diagnostic Laboratory Barnes Jewish Hospital Missouri 26D0438670 84937 | UBE3A | Methylation analysis | PCR-RFLP with Southern hybridization | Peripheral (whole) blood | No | Yes
GTR000248613.1 | Molecular Diagnostic Laboratory LabCorp North Carolina 34D0655205 248613 | 15q11-q13 | Methylation analysis | Methylation-specific PCR | Amniotic fluid\|Buccal swab\|Peripheral (whole) blood | Decline to answer | No
GTR000500320.1 | Molecular Diagnostics Laboratory University of California, San Francisco California 05D1024215 500320 | 15q11.2 | Methylation analysis | Other | Cell culture\|Peripheral (whole) blood | No | Yes
GTR000336254.1 | Molecular Genetics Diagnostic Laboratory Detroit Medical Center University Laboratories Michigan 23D0717194 336254 | UBE3A | Methylation analysis\|Sequence analysis of the entire coding region | Methylation-specific PCR\|Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000193077.1 | Molecular Genetics Laboratory Children’s Mercy Hospital and Clinics Missouri 26D2046586 193077 | 15q11.2-q13 | Deletion/duplication analysis\|Methylation analysis | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Methylation-specific PCR | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000204883.3 | Molecular Genetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 204883 | 15q11-q13 | Methylation analysis | PCR on sodium bisulfite treated DNA | NR | Decline to answer | Yes
GTR000500585.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500585 | CDKL5 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Other\|Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000500696.2 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500696 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000501272.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501272 | SLC9A6\|SNRPN\|UBE3A | Deletion/duplication analysis\|Methylation analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Methylation-specific PCR\|Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501273.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501273 | UBE3A | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501274.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501274 | UBE3A | Sequence analysis of the entire coding region | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501275.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501275 | UBE3A | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501276.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501276 | UBE3A | Targeted variant analysis | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000503131.2 | Natera NR California 05D1082992 503131 | 15q11-q13\|1p36\|22q11.2\|5p\|Chromosome 13\|Chromosome 18\|Chromosome 21\|Human genome\|Sex chromosome X | Targeted variant analysis | SNP Detection | Cell-free DNA\|Maternal blood sample | Decline to answer | No
GTR000507942.2 | Pittsburgh Cytogenetics Laboratory University of Pittsburgh Medical Center Pennsylvania 39D0673863 507942 | ABCB7\|ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|ALAS2\|ALG13\|AMELX\|AMER1\|AP1S2\|AR\|ARHGEF6\|ARHGEF9\|ARSE\|ARX\|ATP2B3\|ATP6AP2\|ATP7A\|ATRX\|AVPR2\|BCOR\|BRWD3\|BTK\|CACNA1F\|CASK\|CDKL5\|CFP\|CHM\|CHRDL1\|CLCN5\|CLIC2\|COL4A5\|COX7B\|CSF2RA\|CYBB\|DCX\|DKC1\|DLG3\|DMD\|EBP\|EDA\|EFNB1\|EMD\|F8\|F9\|FAM58A\|FANCB\|FHL1\|FLNA\|FTSJ1\|G6PD\|GATA1\|GDI1\|GJB1\|GK\|GLA\|GPR143\|GRIA3\|HCCS\|HCFC1\|HDAC8\|HPRT1\|HSD17B10\|IDS\|IGBP1\|IGSF1\|IKBKG\|IL1RAPL1\|IL2RG\|KAL1\|KDM5C\|KDM6A\|L1CAM\|LAMP2\|MAGT1\|MAMLD1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NHS\|NLGN3\|NLGN4X\|NR0B1\|NSDHL\|OCRL\|OFD1\|OPHN1\|OPN1MW\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PHKA1\|PHKA2\|PIGA\|PLP1\|POLA1\|PORCN\|POU3F4\|PQBP1\|PRPS1\|RAB39B\|RAB40AL\|RBM10\|RP2\|RPGR\|RPL10\|RPS6KA3\|RS1\|SAT1\|SERPINA7\|SH2D1A\|SHOX\|SHROOM4\|SLC16A2\|SLC35A2\|SLC6A14\|SLC6A8\|SLC9A6\|SMPX\|SMS\|SOX3\|SRPX2\|SRY\|STS\|SYN1\|SYP\|TAF1\|TAZ\|TBX22\|TIMM8A\|TMLHE\|TRAPPC2\|TSPAN7\|UBA1\|UBE2A\|UBQLN2\|UPF3B\|VMA21\|WAS\|WDR45\|XIAP\|XK\|ZC4H2\|ZDHHC15\|ZDHHC9\|ZIC3\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniotic fluid\|Cell culture\|Chorionic villi\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | No
GTR000504348.1 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 504348 | 15q11.2 | FISH-metaphase | Other | Peripheral (whole) blood | No | Yes
GTR000506039.2 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 506039 | 15q11.2-q13 | FISH-metaphase | Other | Amniocytes\|Chorionic villi\|Peripheral (whole) blood | No | Yes
GTR000501919.2 | Transgenomic Transgenomic Connecticut 07D0995237 501919 | AARS2\|AASS\|ABAT\|ABCB7\|ABCD1\|ABHD5\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADSB\|ACADVL\|ACAT1\|ACSF3\|ACSL4\|ADCK3\|AFG3L2\|AGXT\|AIFM1\|AIFM2\|AK2\|AKR1D1\|ALAS2\|ALDH18A1\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMACR\|AMT\|APEX2\|APTX\|ARG1\|ARMS2\|ASL\|ASS1\|ATL1\|ATM\|ATP5A1\|ATP5B\|ATP5C1\|ATP5D\|ATP5E\|ATP5F1\|ATP5G1\|ATP5G2\|ATP5G3\|ATP5I\|ATP5J\|ATP5O\|ATP7B\|ATPAF1\|ATPAF2\|ATPIF1\|ATXN10\|ATXN7\|AUH\|B4GALT1\|BCKDHA\|BCKDHB\|BCS1L\|BRAF\|BTD\|C10orf2\|C12orf65\|C14orf2\|CAPN3\|CARS2\|CAV3\|CDKL5\|CHKB\|CISD2\|CLN3\|CLN5\|CLN6\|CLN8\|CMC1\|COG1\|COG7\|COG8\|COQ2\|COQ3\|COQ4\|COQ6\|COQ7\|COQ9\|COX10\|COX11\|COX15\|COX17\|COX18\|COX19\|COX4I1\|COX4I2\|COX5A\|COX5B\|COX6A1\|COX6A2\|COX6B1\|COX6C\|COX7A1\|COX7A2\|COX7A2L\|COX7B\|COX7B2\|COX7C\|COX8A\|CPOX\|CPS1\|CPT1A\|CPT2\|CRLS1\|CRYAB\|CTNS\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYC1\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP27A1\|CYP27B1\|CYP7B1\|D2HGDH\|DARS2\|DBT\|DCX\|DECR1\|DGUOK\|DLAT\|DLD\|DLST\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DNM2\|DOLK\|DPAGT1\|DPM1\|DPM3\|EARS2\|ECSIT\|EIF2AK3\|ELOVL4\|ETFA\|ETFB\|ETFDH\|ETHE1\|FA2H\|FARS2\|FASTKD2\|FECH\|FGF14\|FH\|FOXG1\|FOXRED1\|FXN\|GAA\|GAD1\|GAMT\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLA\|GLDC\|GLRX5\|GLUD1\|GNPAT\|GPD2\|GPHN\|HADH\|HADHA\|HADHB\|HARS2\|HAX1\|HCCS\|HFE\|HK1\|HLCS\|HMGCL\|HMGCS2\|HSD17B10\|HSD3B2\|HSPD1\|IARS2\|IDH2\|ISCU\|ITPR1\|IVD\|KARS\|KCNC3\|KCNJ11\|KIAA0196\|KIAA0226\|KIF1B\|KIF5A\|LARS2\|LETM1\|LMBRD1\|LRPPRC\|MAOA\|MAPT\|MARS2\|MCCC1\|MCCC2\|ME2\|MECP2\|MFN2\|MFSD8\|MGAT2\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MPV17\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|MYH7\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA3\|NDUFA4\|NDUFA5\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAB1\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB1\|NDUFB10\|NDUFB11\|NDUFB2\|NDUFB3\|NDUFB4\|NDUFB5\|NDUFB6\|NDUFB7\|NDUFB8\|NDUFB9\|NDUFC1\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NEFL\|NIPA1\|NKX2-1\|NPC1\|NPC2\|NUBPL\|OAT\|OGDH\|OPA1\|OPA3\|OTC\|OXA1L\|OXCT1\|PAFAH1B1\|PANK2\|PARL\|PARS2\|PC\|PCCA\|PCCB\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX13\|PHB\|PHYH\|PLP1\|PMM2\|PNKD\|PNPLA2\|PNPLA3\|POLG\|POLG2\|PPM1B\|PPOX\|PPT1\|PREPL\|PRKCG\|PRODH\|PUS1\|PWAR1\|RARS2\|REEP1\|RFT1\|RMRP\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RRM2B\|RYR1\|SAMHD1\|SARS2\|SCN1A\|SCO1\|SCO2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SGCD\|SLC12A3\|SLC16A2\|SLC19A2\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A16\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC29A3\|SLC2A1\|SLC2A10\|SLC33A1\|SLC35A1\|SLC35C1\|SLC3A1\|SLC52A1\|SLC6A8\|SLC7A9\|SOD1\|SPAST\|SPG11\|SPG20\|SPG7\|SPTBN2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TACO1\|TARS2\|TAZ\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOP1MT\|TPM2\|TPP1\|TRMU\|TSFM\|TTBK2\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCR10\|UQCR11\|UQCRB\|UQCRC1\|UQCRC2\|UQCRFS1\|UQCRH\|UQCRQ\|UROS\|USMG5\|VARS2\|WARS2\|WFS1\|XDH\|XPNPEP3\|YARS2\|ZFYVE26 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000509336.2 | Transgenomic Transgenomic Connecticut 07D0995237 509336 | ABAT\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDK\|BCS1L\|BRAF\|BTD\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCDC88C\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX10\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EOMES\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LRPPRC\|MAGI2\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFAF6\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHLRC1\|NIPBL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RBFOX1\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC4A10\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|STIL\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VDAC1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000025318.1 | United States Air Force, DNA Diagnostic Laboratory United States Air Force Mississippi NR 25318 | UBE3A | Methylation analysis | Methylation-specific PCR | Amniocytes\|Peripheral (whole) blood | No | No
GTR000305769.2 | UW Cytogenetic Services University of Wisconsin - Madison/WSLH Wisconsin 52D0669558 305769 | 15q11-q13 | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis\|Methylation analysis | Fluorescence In Situ Hybridization\|Fluorescence In Situ Hybridization\|Microarray\|Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Cord blood\|Peripheral (whole) blood | Decline to answer | Yes

NR – Not reported

Table D-2 Genetic tests for Autism Spectrum Disorder

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000322654.3 | Ambry Genetics Ambry Genetics California 05D0981414 322654 | CDKL5 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Isolated DNA\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000515184.1 | Athena Diagnostics Inc Massachusetts 22D0069726 515184 | SHANK2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000515188.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515188 | PTEN | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000507870.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 507870 | PTEN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000507872.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 507872 | PTEN | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Not reported | Decline to answer | No
GTR000507873.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 507873 | PTEN | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Not reported | Decline to answer | No
GTR000507874.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 507874 | PTEN | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000507875.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 507875 | PTEN | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000507876.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 507876 | PTEN | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000508280.2 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 508280 | AARS2\|AASS\|ABAT\|ABCA12\|ABCA4\|ABCB11\|ABCB4\|ABCB6\|ABCB7\|ABCD1\|ABHD12\|ABHD5\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACO2\|ACOX1\|ACSF3\|ACSL4\|ADAM9\|ADCK3\|ADSL\|AFG3L2\|AGK\|AGL\|AGPS\|AGXT\|AIFM1\|AIPL1\|AK1\|AK2\|AKAP10\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|ALDOA\|ALDOB\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ALMS1\|AMACR\|AMER1\|AMN\|AMT\|ANKH\|ANKRD26\|AP3B1\|APP\|APTX\|ARG1\|ARL6\|ASL\|ASS1\|ATIC\|ATP5E\|ATP6V0A2\|ATP7A\|ATP7B\|ATP8B1\|ATPAF2\|AUH\|B4GALT1\|B4GALT7\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BCKDHA\|BCKDHB\|BCOR\|BCS1L\|BEST1\|BLOC1S3\|BOLA3\|BRCA1\|BTD\|C10orf2\|C12orf65\|C1QTNF5\|C2orf71\|C8orf37\|CA2\|CA4\|CABP4\|CACNA1F\|CACNA2D4\|CASP8\|CAT\|CBS\|CC2D2A\|CCDC28B\|CCDC39\|CDH23\|CDHR1\|CEP290\|CERKL\|CHAT\|CHM\|CISD2\|CLCN7\|CLN3\|CLRN1\|CNGA1\|CNGA3\|CNGB1\|CNGB3\|COG1\|COG7\|COG8\|COL1A1\|COL1A2\|COL2A1\|COL3A1\|COL5A1\|COL5A2\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|CPOX\|CPS1\|CPT1A\|CPT2\|CRB1\|CRTAP\|CRX\|CRYAB\|CTSA\|CTSD\|CTSK\|CUBN\|CYB5A\|CYB5R3\|CYBA\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP17A1\|CYP1B1\|CYP24A1\|CYP27A1\|CYP27B1\|CYP4V2\|D2HGDH\|DARS2\|DBT\|DDOST\|DFNB31\|DGUOK\|DHDDS\|DHODH\|DIABLO\|DLAT\|DLD\|DMGDH\|DNAJC19\|DNM1L\|DPM1\|DPM3\|DSP\|DTNBP1\|EFEMP1\|ELAC2\|ELN\|ELOVL4\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|EYA1\|EYA4\|EYS\|FAH\|FAM161A\|FAM20C\|FASTKD2\|FBLN5\|FBN1\|FBP1\|FECH\|FH\|FKBP10\|FLVCR1\|FOXC1\|FOXL2\|FOXRED1\|FRMD7\|FSCN2\|FXN\|FYCO1\|FZD4\|G6PC\|GAA\|GAD1\|GALC\|GALE\|GALK1\|GALNS\|GALT\|GAMT\|GARS\|GATM\|GBE1\|GCDH\|GCK\|GCKR\|GCSH\|GFER\|GFM1\|GIF\|GJA3\|GK\|GLB1\|GLDC\|GLRX5\|GLUD1\|GLYCTK\|GM2A\|GNAT1\|GNAT2\|GNE\|GNPTAB\|GNS\|GOT1\|GPD1\|GPD2\|GPI\|GPR143\|GPR98\|GPX1\|GRK1\|GRM6\|GRN\|GSN\|GUCA1A\|GUCA1B\|GUCY2D\|GUSB\|GYS1\|GYS2\|HADHA\|HADHB\|HAGH\|HARS\|HAX1\|HBB\|HCCS\|HESX1\|HEXA\|HEXB\|HGSNAT\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HNF1A\|HNF1B\|HP\|HPRT1\|HPS1\|HPS3\|HPS4\|HPS5\|HPS6\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH2\|IDH3B\|IMPDH1\|IMPG2\|INPP5E\|INVS\|IQCB1\|ISCU\|IVD\|JAG1\|KARS\|KCNJ13\|KCNV2\|KIF1B\|KIF21A\|KLHL7\|KRT12\|KRT3\|KRT5\|L2HGDH\|LCA5\|LDHA\|LDHB\|LEMD3\|LEPRE1\|LIAS\|LMBRD1\|LMX1B\|LPIN1\|LRAT\|LRP5\|LRPPRC\|MAN2B1\|MANBA\|MAOA\|MC1R\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MEF2A\|MEN1\|MERTK\|MFN2\|MFRP\|MGAT2\|MKKS\|MKS1\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MPDU1\|MPI\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MSRB3\|MTHFR\|MTO1\|MTPAP\|MTR\|MTRR\|MUT\|MUTYH\|MYO7A\|MYOC\|NAGLU\|NAGS\|NCOA4\|NDP\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NEFH\|NEUROD1\|NFU1\|NHS\|NME1\|NPHP1\|NPHP3\|NPHP4\|NRL\|NT5C3A\|NUBPL\|NYX\|OAT\|OCA2\|OCRL\|OGDH\|OGG1\|OPA1\|OPA3\|OPN1LW\|OPN1MW\|OPTN\|OSTM1\|OTC\|OTX2\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PAX2\|PAX6\|PC\|PCCA\|PCCB\|PCDH15\|PCK2\|PDE6A\|PDE6B\|PDE6C\|PDE6G\|PDHA1\|PDHB\|PDP1\|PDSS1\|PDSS2\|PDZD7\|PFKM\|PGAM2\|PGM1\|PHB\|PHKA1\|PHKA2\|PHKB\|PHKG2\|PHOX2A\|PHYH\|PINK1\|PITPNM3\|PITX2\|PITX3\|PLA2G2A\|PLOD2\|PLOD3\|PMM2\|PNKD\|PNPLA2\|POLG\|POLG2\|PPARG\|PPARGC1B\|PPIB\|PPOX\|PPP2R1B\|PRCD\|PRKCG\|PRODH\|PROM1\|PRPF31\|PRPF6\|PRPF8\|PRPH2\|PSAP\|PSEN1\|PTRF\|PTS\|PUS1\|PYCR1\|PYGL\|PYGM\|QDPR\|RAF1\|RARS2\|RAX\|RB1\|RD3\|RDH12\|RDH5\|REEP1\|RET\|RFT1\|RGR\|RGS9\|RHO\|RILP\|RIMS1\|RLBP1\|RNASEL\|RP1\|RP1L1\|RP2\|RP9\|RPE65\|RPGR\|RPGRIP1\|RPL35A\|RPS14\|RRM2B\|RS1\|SAG\|SARDH\|SARS2\|SCO2\|SCP2\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SECISBP2\|SEMA4A\|SEPT9\|SERPINF1\|SGSH\|SHH\|SIX6\|SLC16A1\|SLC22A4\|SLC22A5\|SLC24A1\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC26A4\|SLC34A1\|SLC35A1\|SLC35C1\|SLC37A4\|SLC39A13\|SLC3A1\|SLC45A2\|SLC9A3R1\|SLC9A6\|SMPD1\|SNCB\|SNRNP200\|SOD1\|SOD2\|SOST\|SOX2\|SP7\|SPATA7\|SPG7\|SPR\|SPTLC2\|SQSTM1\|SRD5A3\|STAR\|STAT1\|STAT3\|STRA6\|STXBP1\|SUCLA2\|SUCLG1\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TCN2\|TEAD1\|TGFB1\|TGFBI\|TIMM8A\|TIMP3\|TK2\|TLR3\|TLR4\|TMEM126A\|TMEM127\|TMEM67\|TMEM70\|TNFRSF11A\|TNFRSF11B\|TNFSF11\|TOPORS\|TP53\|TPP1\|TRIM32\|TRMU\|TRPM1\|TSFM\|TSPAN12\|TTC19\|TTC8\|TUBA1A\|TUBB3\|TUFM\|TULP1\|TUSC3\|TYMP\|TYR\|TYROBP\|TYRP1\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|USH1C\|USH1G\|USH2A\|VCP\|VHL\|VSX1\|WFS1\|WT1\|WWOX\|XDH\|XPNPEP3\|YARS2\|ZEB1\|ZFHX3\|ZNF513 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | Not reported | Not reported
GTR000512051.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512051 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512052.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512052 | MECP2 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | Not reported | No
GTR000512053.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512053 | MECP2 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | Not reported | No
GTR000512054.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512054 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512055.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512055 | MECP2 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512056.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512056 | MECP2 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000243196.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 243196 | NLGN3\|NLGN4X\|SNRPN | FISH-metaphase\|Sequence analysis of the entire coding region | Fluorescence in situ Hybridization (FISH)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000311732.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 311732 | PTEN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000295241.1 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 295241 | Human genome | Detection of homozygosity\|Detection of homozygosity | SNP Detection\|SNP Detection | Amniocytes\|Amniotic fluid\|Bone marrow\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fetal blood\|Fibroblasts\|Isolated DNA\|Product of conception (POC)\|Saliva\|Skin | Decline to answer | No
GTR000500030.2 | Clinical Molecular Genetics Diagnostic Laboratory University of Miami Miller School of Medicine Florida 10D2024894 500030 | Human genome | Deletion/duplication analysis | Microarray | Peripheral (whole) blood | Yes (Pre-Test), Decline to Answer (Post-Test) | Yes
GTR000500883.8 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500883 | ABAT\|ABCC2\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|AKT3\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASAH1\|ASPA\|ASPM\|ATIC\|ATN1\|ATP1A2\|ATP1A3\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BRAF\|BRAT1\|BRD2\|BTD\|BUB1B\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT1A\|CPT2\|CSTB\|CTSA\|CTSD\|CTSF\|CUL4B\|CYP1B1\|CYP2A6\|CYP2B6\|CYP2C19\|CYP2C9\|CYP2D6\|CYP2R1\|CYP2U1\|CYP3A5\|DBT\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FAAH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FOXH1\|FUCA1\|GABBR2\|GABRA1\|GABRA2\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDH2\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIAS\|LIG4\|LRPPRC\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED12\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NGLY1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPA1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PIK3CA\|PIK3R2\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|RTTN\|SAMHD1\|SCARB2\|SCN10A\|SCN11A\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGCE\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SNIP1\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|ST3GAL5\|STIL\|STRADA\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TRPM6\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | No
GTR000500936.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500936 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|C21orf33\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|G6PD\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|HTT\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000503671.2 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 503671 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000308062.1 | DNA Diagnostic Laboratory at Johns Hopkins Johns Hopkins Hospital Maryland 21D0692357 308062 | PTEN | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000501369.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501369 | PTEN | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501370.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501370 | PTEN | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501803.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501803 | NLGN3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501804.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501804 | NLGN3 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501805.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501805 | NLGN4X | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501807.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501807 | NLGN4X | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501810.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501810 | Human genome | Karyotyping | Microarray | Cord blood\|Dried blood spot (DBS) card\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000501811.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501811 | Human genome | Karyotyping | Microarray | Cord blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood | No | No
GTR000502463.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502463 | NRXN1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502464.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502464 | NRXN1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502824.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502824 | RPL10 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502826.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502826 | RPL10 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000503014.3 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503014 | Not reported | Analyte | Dimethylene Blue binding Quantitation and Thin Layer Chromatography\|GC-MS\|Isotope dilution, LC-MS/MS\|MALDI-TOF/TOF\|ion-exchange chromatography | Plasma\|Urine | No | No
GTR000503286.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503286 | FMR1, Human Genome | Analyte\|Karyotyping\|Targeted variant analysis | Dimethylene Blue binding Quantitation and Thin Layer Chromatography\|GC-MS/MS\|Ion-Exchange Chromatography\|Isotope dilution method by LC-MS/MS\|MALDI-TOF/TOF\|Comparative Genomic Hybridization\|Trinucleotide repeat by PCR or Southern Blot | Not reported | No | No
GTR000503288.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503288 | FMR1, Human Genome | Karyotyping\|Targeted variant analysis | Comparative Genomic Hybridization\|Trinucleotide repeat by PCR or Southern Blot | Not reported | No | No
GTR000512416.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512416 | ABAT\|ADSL\|ALDH7A1\|ARHGEF9\|ARX\|ASPM\|ATP1A2\|ATP6AP2\|BCKDK\|CACNA1A\|CACNB4\|CASK\|CASR\|CDKL5\|CENPJ\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CPA6\|CSTB\|CTSD\|DCX\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FLNA\|FOLR1\|FOXG1\|GABRA1\|GABRG2\|GAMT\|GATM\|GOSR2\|GPR56\|GPR98\|GRIN2A\|HCN1\|HCN4\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|LGI1\|LIAS\|MAGI2\|MBD5\|MCPH1\|MECP2\|MEF2C\|MFSD8\|MTHFR\|NDE1\|NDUFA1\|NHLRC1\|NRXN1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PLCB1\|PNKP\|PNPO\|POLG\|PPT1\|PRICKLE1\|PRICKLE2\|PRRT2\|RELN\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN3A\|SCN8A\|SCN9A\|SHH\|SIX3\|SLC19A3\|SLC25A19\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|SRPX2\|ST3GAL3\|ST3GAL5\|STIL\|STXBP1\|SYN1\|TBC1D24\|TCF4\|TPP1\|TSC1\|TSC2\|TSEN54\|UBE3A\|WDR62\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512417.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512417 | ADAM17\|AICDA\|ATG16L1\|BTK\|C1orf106\|CD40LG\|COL7A1\|CYBA\|CYBB\|DCLRE1C\|DOCK8\|ERAP2\|FERMT1\|FOXP3\|FUT2\|G6PC3\|GUCY2C\|HPS1\|HPS4\|HPS6\|ICOS\|IL10\|IL10RA\|IL18RAP\|IL23R\|IL2RA\|IRGM\|ITGAM\|LRBA\|MEFV\|MVK\|NCF2\|NCF4\|NOD2\|PIK3R1\|PLCG2\|PTEN\|PTPN22\|RAC2\|RB1\|RET\|SH2D1A\|SLC37A4\|STAT1\|STXBP2\|TTC37\|WAS\|XIAP | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512586.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512586 | ABCD1\|ACSL4\|AFF2\|AP1S2\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDK16\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|HCCS\|HCFC1\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|KLF8\|L1CAM\|LAMP2\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SYN1\|SYP\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|ZDHHC15\|ZDHHC9\|ZNF711 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512587.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512587 | ADSL\|AFF2\|AP1S2\|ARX\|ATRX\|BCKDK\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DHCR7\|DMD\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|HPRT1\|KDM5C\|L1CAM\|MAGEL2\|MBD5\|MECP2\|MED12\|MEF2C\|MID1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NR1I3\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RELN\|SCN1A\|SLC2A1\|SLC9A6\|SMARCB1\|SMC1A\|TCF4\|UBE2A\|UBE3A\|VPS13B\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512606.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512606 | CUL4B\|EZH2\|GLI3\|GPC3\|MED12\|NFIX\|NSD1\|PHF6\|PTCH1\|PTEN\|UPF3B | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512650.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512650 | ALK\|APC\|ATM\|BMPR1A\|BRCA1\|BRCA2\|BRIP1\|CDC73\|CDH1\|CDKN1C\|CDKN2A\|CHEK2\|EPCAM\|FH\|FLCN\|GPC3\|MAX\|MEN1\|MET\|MLH1\|MSH2\|MSH6\|MUTYH\|NBN\|NF2\|PALB2\|PHOX2B\|PMS1\|PMS2\|PRKAR1A\|PTCH1\|PTEN\|RAD51C\|RAD51D\|RET\|SDHAF2\|SDHB\|SDHC\|SDHD\|SMAD4\|STK11\|SUFU\|TMEM127\|TP53\|VHL\|WT1 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000507957.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 507957 | APC\|AXIN2\|BMPR1A\|BUB1B\|CDH1\|CDKN2A\|CHEK2\|EPCAM\|EXO1\|FLCN\|GALNT12\|MLH1\|MSH2\|MSH6\|MUTYH\|PMS1\|PMS2\|PTEN\|SMAD4\|STK11\|TP53 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000507985.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 507985 | BRCA1\|BRCA2\|CDK4\|CDKN2A\|ERCC3\|MC1R\|MITF\|PTEN\|RB1\|TERT\|TP53\|TYR\|WRN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000508339.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 508339 | APC\|ATM\|ATR\|AXIN2\|BAP1\|BARD1\|BLM\|BMPR1A\|BRCA1\|BRCA2\|BRIP1\|CDH1\|CDK4\|CDKN2A\|CHEK2\|CTNNB1\|EPCAM\|FANCC\|HOXB13\|MLH1\|MRE11A\|MSH2\|MSH6\|MUTYH\|NBN\|PALB2\|PALLD\|PMS2\|PTEN\|RAD50\|RAD51\|RAD51C\|RAD51D\|SMAD4\|STK11\|TP53\|VHL\|XRCC2\|XRCC3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509342.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509342 | ANKRD11\|AP1S2\|ARX\|ATRX\|AUTS2\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CHD8\|CNTNAP2\|CNTNAP5\|CREBBP\|DHCR7\|DLGAP2\|DMD\|DOCK4\|DPP10\|DPP6\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GABRG1\|GNA14\|GRIN2B\|GRPR\|HOXA1\|HPRT1\|IMMP2L\|KATNAL2\|KCTD13\|KDM5C\|KIRREL3\|KLHL3\|L1CAM\|LAMC3\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|NEGR1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRXN1\|NSD1\|NTNG1\|OPHN1\|PAFAH1B1\|PCDH19\|PCDH9\|PDE10A\|PHF6\|PIP5K1B\|PNKP\|PON3\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RBFOX1\|RELN\|RPL10\|SATB2\|SCN1A\|SCN2A\|SHANK2\|SHANK3\|SLC6A4\|SLC9A6\|SLC9A9\|SMC1A\|SMG6\|SNRPN\|SOX5\|SPAST\|ST7\|STK3\|TCF4\|TSC1\|TSC2\|UBE3A\|VPS13B\|ZEB2\|ZNF507\|ZNF804A\|ZNHIT6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509399.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509399 | ABAT\|ABCB1\|ABCC8\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCS1L\|BRAF\|BTD\|BUB1B\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COG1\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|EFHC1\|EFHC2\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HCN1\|HCN4\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|IDS\|IDUA\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIG4\|LRPPRC\|MAGI2\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MLC1\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDSS1\|PDSS2\|PEX1\|PEX12\|PEX14\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PHF6\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN10A\|SCN1A\|SCN1B\|SCN2A\|SCN2B\|SCN3A\|SCN3B\|SCN4A\|SCN4B\|SCN5A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC17A5\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35C1\|SLC46A1\|SLC6A5\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRPX2\|STIL\|STXBP1\|SUMF1\|SUOX\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509427.10 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509427 | AIP\|APC\|ATM\|ATR\|AXIN2\|BAP1\|BARD1\|BLM\|BMPR1A\|BRCA1\|BRCA2\|BRIP1\|BUB1B\|CDH1\|CDK4\|CDKN1B\|CDKN2A\|CHEK2\|CTNNB1\|CYLD\|DDB2\|DICER1\|EGFR\|EGLN1\|EPCAM\|ERCC2\|ERCC3\|ERCC4\|ERCC5\|EXO1\|EXT1\|EXT2\|FANCA\|FANCB\|FANCC\|FANCD2\|FANCE\|FANCF\|FANCG\|FANCI\|FANCL\|FANCM\|FH\|FLCN\|GALNT12\|GPC3\|HOXB13\|HRAS\|KIF1B\|KIT\|MAX\|MC1R\|MEN1\|MET\|MITF\|MLH1\|MPL\|MRE11A\|MSH2\|MSH3\|MSH6\|MUTYH\|NBN\|NF1\|NF2\|PALB2\|PDGFRA\|PICALM\|PMS1\|PMS2\|POLD1\|PRKAR1A\|PRKDC\|PRSS1\|PTCH1\|PTEN\|PTPN11\|RAD50\|RAD51\|RAD51C\|RAD51D\|RB1\|RBBP8\|RBM15\|RECQL4\|RET\|ROBO2\|SBDS\|SDHA\|SDHAF2\|SDHB\|SDHC\|SDHD\|SLX4\|SMAD4\|SMARCB1\|STK11\|SUFU\|TERT\|TMEM127\|TP53\|TSC1\|TSC2\|TSHR\|TYR\|VHL\|WRN\|WT1\|XPA\|XPC\|XRCC2\|XRCC3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509431.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509431 | ABAT\|ACOX1\|ALDH3A2\|ARSA\|ASPA\|CSF1R\|DARS2\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|FAM126A\|GFAP\|GJC2\|HEPACAM\|HSPD1\|HTRA1\|LMNB1\|MLC1\|NOTCH3\|PLP1\|PSAP\|PTEN\|SCP2\|SLC25A12 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509442.11 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509442 | ABCC6\|ABCD1\|ABCG5\|ACAT1\|ACOX1\|ACSL4\|ACY1\|ADAR\|ADSL\|AFF2\|AFP\|AGL\|AGT\|AGTR2\|AHI1\|AIFM1\|ALDH18A1\|ALDH4A1\|ALG11\|ALG12\|ALG6\|ALX4\|AMER1\|AP1S1\|AP1S2\|AP3B1\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|APOB\|AQP7\|AR\|ARG1\|ARHGEF6\|ARID1A\|ARID1B\|ARX\|ASPM\|ASS1\|ATL1\|ATM\|ATP13A2\|ATP1A2\|ATP6AP2\|ATP7A\|ATRX\|AUH\|AVP\|AVPR2\|BBS9\|BCS1L\|BIN1\|BRCA2\|BRIP1\|BRWD3\|BUB1B\|CACNG2\|CAMTA1\|CANT1\|CASK\|CBS\|CC2D1A\|CC2D2A\|CCDC88C\|CDH15\|CDKL5\|CDKN1C\|CEP290\|CEP41\|CEP57\|CHD7\|CHRNA4\|CLN3\|CNTNAP2\|COG5\|COG7\|COL1A2\|CP\|CPA6\|CPS1\|CRADD\|CRBN\|CTC1\|CTNNB1\|CTSA\|CUL4B\|CYB5R3\|CYP27A1\|D2HGDH\|DARS2\|DBT\|DHCR24\|DHCR7\|DIP2B\|DLG3\|DMD\|DPYD\|DYNC1H1\|DYRK1A\|EBP\|EFNB1\|EHMT1\|ELOVL4\|ERCC2\|ERCC3\|ERCC5\|ERCC6\|ERCC8\|F5\|FAM126A\|FANCG\|FBLN5\|FBN1\|FBN2\|FGD1\|FGF14\|FGFR1\|FGFR2\|FGFR3\|FKRP\|FKTN\|FMR1\|FOXG1\|FOXP1\|FTO\|FTSJ1\|G6PC3\|GABRG2\|GALE\|GAMT\|GAN\|GBA\|GBE1\|GCK\|GDI1\|GFAP\|GFM1\|GHR\|GLI3\|GLRA1\|GLUL\|GLYCTK\|GM2A\|GNAS\|GNPAT\|GNPTAB\|GNPTG\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|GRM1\|GSS\|GUSB\|GYS2\|HAX1\|HDAC4\|HDAC8\|HEPACAM\|HEXB\|HOXD10\|HPD\|HSD17B10\|HSPD1\|HUWE1\|IDS\|IGBP1\|IGF1\|IGF1R\|IL1RAPL1\|INSR\|IQSEC2\|IRX5\|ITGA7\|KCNJ10\|KCNJ11\|KCNK9\|KCNQ2\|KCTD7\|KDM5C\|KIF11\|KIF1A\|KIF21A\|KIF5A\|KIF7\|KIRREL3\|KRAS\|L1CAM\|LAMA2\|LAMP2\|LARGE\|LBR\|LHX3\|LIG4\|LMBRD1\|LRP5\|LYST\|MAGT1\|MAN1B1\|MAN2B1\|MANBA\|MAPT\|MAT1A\|MBD5\|MBTPS2\|MCCC1\|MCCC2\|MCOLN1\|MCPH1\|MECP2\|MED17\|MED23\|MEF2C\|MFSD8\|MGAT2\|MKKS\|MMADHC\|MOCS2\|MPI\|MPZ\|MRAP\|MTFMT\|MTHFR\|MTR\|MYCN\|MYO5A\|MYO7A\|NAGA\|NBN\|NDP\|NDUFA1\|NDUFAF5\|NDUFS1\|NF1\|NGF\|NHEJ1\|NHP2\|NIPBL\|NLGN3\|NPC1\|NPC2\|NPHP3\|NRXN1\|NSDHL\|NSUN2\|OFD1\|OPHN1\|ORC1\|PAFAH1B1\|PAH\|PAK3\|PAX6\|PCDH19\|PCNT\|PDE4D\|PDHX\|PDSS1\|PEX7\|PGK1\|PHF8\|PHKA2\|PHKG2\|PIGL\|PIGO\|PIGV\|PLA2G6\|PLP1\|POMGNT1\|POMT1\|POMT2\|POU1F1\|PPOX\|PQBP1\|PRICKLE1\|PRKAR1A\|PRSS12\|PTEN\|PTPN11\|PYCR1\|PYGL\|RAB39B\|RAB40AL\|RAI1\|RAPSN\|RBBP8\|RBM10\|RFX6\|RPGRIP1L\|RPS6KA3\|SACS\|SAMHD1\|SATB2\|SCN1A\|SCN8A\|SDCCAG8\|SGCA\|SGSH\|SHANK2\|SHANK3\|SHROOM4\|SIL1\|SLC16A2\|SLC20A2\|SLC25A12\|SLC25A13\|SLC25A15\|SLC2A1\|SLC2A2\|SLC35C1\|SLC46A1\|SLC4A4\|SLC5A2\|SLC5A5\|SLC6A4\|SLC6A8\|SLC7A7\|SLC9A6\|SLX4\|SMARCA4\|SMARCB1\|SMC1A\|SMS\|SNIP1\|SOBP\|SOX10\|SOX2\|SOX3\|SPR\|SPTAN1\|SPTLC1\|SRD5A3\|SRPX2\|ST3GAL3\|STAT5B\|STRA6\|STX11\|STXBP1\|SUCLG1\|SYNGAP1\|SYP\|SYT14\|TBC1D24\|TBCE\|TBX1\|TECR\|TGIF1\|TH\|THRB\|TINF2\|TMCO1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPH2\|TPK1\|TRAPPC9\|TRHR\|TSC1\|TSC2\|TSHR\|TSPAN7\|TTC37\|TTR\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|TUSC3\|TWIST1\|UBE2A\|UBE3A\|UPB1\|UPF3B\|UROC1\|USP9X\|VLDLR\|VPS13B\|WDR62\|WDR81\|WRN\|XIST\|XPNPEP3\|ZBTB16\|ZBTB24\|ZDHHC9\|ZEB2\|ZFP57\|ZFYVE26\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | Not reported | Not reported
GTR000509443.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509443 | ALDH7A1\|ARX\|ATP1A2\|CACNA1A\|CDKL5\|FOLR1\|FOXG1\|GAMT\|KCNQ2\|MECP2\|PCDH19\|PHGDH\|PNPO\|POLG\|PPT1\|SCN1A\|SLC2A1\|STXBP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509462.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509462 | ARX\|ATRX\|CAV1\|CDKL5\|CNTNAP2\|FOXG1\|MECP2\|MED17\|MEF2C\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|TRAPPC9\|UBE3A\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510869.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510869 | BRAF\|HRAS\|KRAS\|MUTYH\|NRAS\|PTEN\|RET\|SDHB\|SDHD\|TP53 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510914.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510914 | BAP1\|EPCAM\|FH\|FLCN\|MET\|MITF\|MLH1\|MSH2\|MSH6\|PMS2\|PTEN\|SDHA\|SDHB\|SDHC\|SDHD\|TP53\|TSC1\|TSC2\|VHL | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510915.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510915 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ABCD3\|ACACA\|ACACB\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACLY\|ACO2\|ACSF3\|ACSL4\|ACSL5\|ACSM3\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AGXT2\|AIFM1\|AK2\|AKAP10\|AKR7A2\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|AS3MT\|ASS1\|ATIC\|ATP10D\|ATP5E\|ATP5SL\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BAX\|BCAT1\|BCAT2\|BCKDHA\|BCKDHB\|BCL2\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDC42BPB\|CDKL5\|CFTR\|CHAT\|CHDH\|CHRNA4\|CHRNB2\|CISD2\|CKM\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CLYBL\|CNR1\|COA5\|COMT\|COQ2\|COQ4\|COQ5\|COQ6\|COQ9\|COX10\|COX15\|COX4I1\|COX4I2\|COX6B1\|COX7A2\|CPOX\|CPS1\|CPT1A\|CPT1B\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDAH1\|DDC\|DECR1\|DGUOK\|DHODH\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNAJC5\|DNM1L\|DTNBP1\|EARS2\|ECI1\|ECSIT\|ELAC2\|ELN\|ENO1\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FAAH\|FARS2\|FASN\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FPGS\|FTH1\|FXN\|G6PC\|G6PD\|GAD1\|GAD2\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLO1\|GLRA1\|GLRX5\|GLS\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPAM\|GPD1\|GPD2\|GPI\|GPX1\|GPX4\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HARS\|HARS2\|HCCS\|HIBCH\|HIGD2A\|HK1\|HK2\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B1\|HSD3B2\|HSPA9\|HSPB7\|HSPD1\|HTRA2\|HTT\|IDE\|IDH1\|IDH2\|IDH3B\|IMMP2L\|IMMT\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|KYNU\|L2HGDH\|LARS2\|LDHA\|LDHB\|LETM1\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MAOB\|MARS2\|MAVS\|MCCC1\|MCCC2\|MCEE\|MDH1\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MGLL\|MGST3\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCOS\|MOCS1\|MOCS2\|MOGS\|MRPL3\|MRPL48\|MRPS16\|MRPS22\|MRRF\|MTCH2\|MTFMT\|MTHFD1\|MTHFD1L\|MTHFS\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA4\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB1\|NDUFB3\|NDUFB6\|NDUFB9\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NFU1\|NIPSNAP1\|NIPSNAP3A\|NLRX1\|NME1\|NOS3\|NPL\|NRXN1\|NTHL1\|NUBPL\|OAT\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PACRG\|PAH\|PAK7\|PANK2\|PARK2\|PARL\|PARP1\|PC\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PKLR\|PMPCA\|PNKD\|PNMT\|POLG\|POLG2\|POLRMT\|PPARGC1A\|PPARGC1B\|PPOX\|PPT1\|PREPL\|PRODH\|PTGES2\|PTS\|PUS1\|PYCR1\|QDPR\|RAB11FIP5\|RARS2\|REEP1\|RNASEL\|RPL35A\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SHMT1\|SIRT1\|SIRT3\|SIRT5\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A39\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|TACO1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TFAM\|TFB1M\|TIMM44\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOMM40\|TOP1MT\|TP53\|TPH2\|TPI1\|TPP1\|TRMU\|TSFM\|TSPO\|TST\|TTC19\|TUFM\|TXN2\|TXNRD2\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|USP24\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510916.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510916 | ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|AP1S2\|ARHGEF6\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|EBP\|FAAH2\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|GSPT2\|HCCS\|HDAC8\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|L1CAM\|LAMP2\|MAGT1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RAB40AL\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SRPX2\|SYN1\|SYP\|TAF1\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|USP9X\|WDR13\|ZCCHC12\|ZDHHC15\|ZDHHC9\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000327662.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 327662 | AP1S2\|ARX\|ASPM\|ATRX\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CBL\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DCX\|DHCR7\|DMD\|EHMT1\|ERCC6\|ERCC8\|FGD1\|FGFR1\|FGFR2\|FGFR3\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|HDAC8\|HOXA1\|HPRT1\|HRAS\|KDM5C\|KMT2D\|KRAS\|L1CAM\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|MKKS\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCH1\|PTEN\|PTPN11\|RAB39B\|RAD21\|RAF1\|RAI1\|RELN\|RPGRIP1L\|RPS6KA3\|SCN1A\|SHANK2\|SHANK3\|SHOC2\|SLC2A1\|SLC6A4\|SLC9A6\|SMC1A\|SMC3\|SOS1\|SPRED1\|TCF4\|TSC1\|TSC2\|TUBA1A\|UBE3A\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | No | No
GTR000515046.3 | Illumina Clinical Services Laboratory Illumina California 05D1092911 515046 | 1,578 genes and variants | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA/Peripheral (whole) blood | Not reported | Yes
GTR000501388.2 | Lineagen, Inc — Utah 46D2042721 501388 | Human genome | Deletion/duplication analysis | Microarray | Buccal swab\|Peripheral (whole) blood | No | Yes
GTR000331296.1 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 331296 | CDKL5\|MBD5\|NLGN3\|NLGN4X\|SHANK2\|SHANK3\|SLC9A6\|TCF4\|UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Isolated DNA | Decline to answer | No
GTR000332993.1 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 332993 | MECP2\|PTEN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Isolated DNA | Decline to answer | No
GTR000508887.1 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 508887 | SHANK3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000508888.1 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 508888 | Human genome | Deletion/duplication analysis | Microarray\|Real Time Quantitative PCR | Peripheral (whole) blood | Decline to answer | Yes
GTR000509356.1 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 509356 | CDKL5 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000509437.3 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 509437 | MEF2C | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000509438.3 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 509438 | UBE3A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000509439.3 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 509439 | SHANK2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000500624.2 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500624 | FMR1 | Targeted variant analysis | PCR with allele specific hybridization | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Dried blood spot (DBS) card\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Serum\|Skin | No | No
GTR000500625.3 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500625 | Human genome | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Dried blood spot (DBS) card\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Serum\|Skin | No | Yes
GTR000500546.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500546 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000500741.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500741 | PTEN | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Peripheral (whole) blood | Decline to answer | No
GTR000500742.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500742 | PTEN | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | No
GTR000500755.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500755 | PTEN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Other\|Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000503364.3 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503364 | PTEN | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000503365.2 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503365 | PTEN | Deletion/duplication analysis | Microarray | Not reported | Decline to answer | No
GTR000511640.1 | Molecular Genetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 511640 | PTEN | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | Yes
GTR000500513.1 | Mount Sinai Genetic Testing Laboratory Icahn School of Medicine at Mount Sinai New York 33D0653419 500513 | Human genome | Karyotyping | Microarray | Fetal blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Please visit http://www.mssm.edu/genetictesting for test specifi\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin | Yes | Yes
GTR000507942.2 | Pittsburgh Cytogenetics Laboratory University of Pittsburgh Medical Center Pennsylvania 39D0673863 507942 | ABCB7\|ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|ALAS2\|ALG13\|AMELX\|AMER1\|AP1S2\|AR\|ARHGEF6\|ARHGEF9\|ARSE\|ARX\|ATP2B3\|ATP6AP2\|ATP7A\|ATRX\|AVPR2\|BCOR\|BRWD3\|BTK\|CACNA1F\|CASK\|CDKL5\|CFP\|CHM\|CHRDL1\|CLCN5\|CLIC2\|COL4A5\|COX7B\|CSF2RA\|CYBB\|DCX\|DKC1\|DLG3\|DMD\|EBP\|EDA\|EFNB1\|EMD\|F8\|F9\|FAM58A\|FANCB\|FHL1\|FLNA\|FTSJ1\|G6PD\|GATA1\|GDI1\|GJB1\|GK\|GLA\|GPR143\|GRIA3\|HCCS\|HCFC1\|HDAC8\|HPRT1\|HSD17B10\|IDS\|IGBP1\|IGSF1\|IKBKG\|IL1RAPL1\|IL2RG\|KAL1\|KDM5C\|KDM6A\|L1CAM\|LAMP2\|MAGT1\|MAMLD1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NHS\|NLGN3\|NLGN4X\|NR0B1\|NSDHL\|OCRL\|OFD1\|OPHN1\|OPN1MW\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PHKA1\|PHKA2\|PIGA\|PLP1\|POLA1\|PORCN\|POU3F4\|PQBP1\|PRPS1\|RAB39B\|RAB40AL\|RBM10\|RP2\|RPGR\|RPL10\|RPS6KA3\|RS1\|SAT1\|SERPINA7\|SH2D1A\|SHOX\|SHROOM4\|SLC16A2\|SLC35A2\|SLC6A14\|SLC6A8\|SLC9A6\|SMPX\|SMS\|SOX3\|SRPX2\|SRY\|STS\|SYN1\|SYP\|TAF1\|TAZ\|TBX22\|TIMM8A\|TMLHE\|TRAPPC2\|TSPAN7\|UBA1\|UBE2A\|UBQLN2\|UPF3B\|VMA21\|WAS\|WDR45\|XIAP\|XK\|ZC4H2\|ZDHHC15\|ZDHHC9\|ZIC3\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniotic fluid\|Cell culture\|Chorionic villi\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | No
GTR000504341.2 | Quest Diagnostics Nichols Institute Chantilly — Virginia 49D0221801 504341 | Human genome | Deletion/duplication analysis | Microarray\|SNP Detection | Cord blood\|Peripheral (whole) blood | No | Yes
GTR000504346.1 | Quest Diagnostics Nichols Institute Chantilly — Virginia 49D0221801 504346 | Human genome | Karyotyping\|Deletion/duplication analysis | G-banding\|Microarray\|SNP Detection | Peripheral (whole) blood | No | Yes
GTR000504349.1 | Quest Diagnostics Nichols Institute Chantilly — Virginia 49D0221801 504349 | Human genome | Karyotyping\|Deletion/duplication analysis | G-banding\|Microarray\|SNP Detection | Peripheral (whole) blood | No | Yes
GTR000506028.2 | Quest Diagnostics Nichols Institute San Juan Capistrano — California 05D0643352 506028 | Human genome | Deletion/duplication analysis | Microarray\|SNP Detection | Cord blood\|Peripheral (whole) blood | No | Yes
GTR000506033.2 | Quest Diagnostics Nichols Institute San Juan Capistrano — California 05D0643352 506033 | Human genome | Karyotyping\|Deletion/duplication analysis | G-banding\|Microarray\|SNP Detection | Peripheral (whole) blood | No | Yes
GTR000506036.2 | Quest Diagnostics Nichols Institute San Juan Capistrano — California 05D0643352 506036 | Human genome | Karyotyping\|Deletion/duplication analysis | G-banding\|Microarray\|SNP Detection | Peripheral (whole) blood | No | Yes
GTR000506042.1 | Quest Diagnostics Nichols Institute San Juan Capistrano — California 05D0643352 506042 | 15q11-q13 | FISH-interphase | Other | Peripheral (whole) blood | No | Yes
GTR000335197.2 | Transgenomic Transgenomic Connecticut 07D0995237 335197 | PTEN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Fresh tissue\|Frozen tissue\|Paraffin block | Decline to answer | Yes
GTR000501919.2 | Transgenomic Transgenomic Connecticut 07D0995237 501919 | AARS2\|AASS\|ABAT\|ABCB7\|ABCD1\|ABHD5\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADSB\|ACADVL\|ACAT1\|ACSF3\|ACSL4\|ADCK3\|AFG3L2\|AGXT\|AIFM1\|AIFM2\|AK2\|AKR1D1\|ALAS2\|ALDH18A1\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMACR\|AMT\|APEX2\|APTX\|ARG1\|ARMS2\|ASL\|ASS1\|ATL1\|ATM\|ATP5A1\|ATP5B\|ATP5C1\|ATP5D\|ATP5E\|ATP5F1\|ATP5G1\|ATP5G2\|ATP5G3\|ATP5I\|ATP5J\|ATP5O\|ATP7B\|ATPAF1\|ATPAF2\|ATPIF1\|ATXN10\|ATXN7\|AUH\|B4GALT1\|BCKDHA\|BCKDHB\|BCS1L\|BRAF\|BTD\|C10orf2\|C12orf65\|C14orf2\|CAPN3\|CARS2\|CAV3\|CDKL5\|CHKB\|CISD2\|CLN3\|CLN5\|CLN6\|CLN8\|CMC1\|COG1\|COG7\|COG8\|COQ2\|COQ3\|COQ4\|COQ6\|COQ7\|COQ9\|COX10\|COX11\|COX15\|COX17\|COX18\|COX19\|COX4I1\|COX4I2\|COX5A\|COX5B\|COX6A1\|COX6A2\|COX6B1\|COX6C\|COX7A1\|COX7A2\|COX7A2L\|COX7B\|COX7B2\|COX7C\|COX8A\|CPOX\|CPS1\|CPT1A\|CPT2\|CRLS1\|CRYAB\|CTNS\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYC1\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP27A1\|CYP27B1\|CYP7B1\|D2HGDH\|DARS2\|DBT\|DCX\|DECR1\|DGUOK\|DLAT\|DLD\|DLST\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DNM2\|DOLK\|DPAGT1\|DPM1\|DPM3\|EARS2\|ECSIT\|EIF2AK3\|ELOVL4\|ETFA\|ETFB\|ETFDH\|ETHE1\|FA2H\|FARS2\|FASTKD2\|FECH\|FGF14\|FH\|FOXG1\|FOXRED1\|FXN\|GAA\|GAD1\|GAMT\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLA\|GLDC\|GLRX5\|GLUD1\|GNPAT\|GPD2\|GPHN\|HADH\|HADHA\|HADHB\|HARS2\|HAX1\|HCCS\|HFE\|HK1\|HLCS\|HMGCL\|HMGCS2\|HSD17B10\|HSD3B2\|HSPD1\|IARS2\|IDH2\|ISCU\|ITPR1\|IVD\|KARS\|KCNC3\|KCNJ11\|KIAA0196\|KIAA0226\|KIF1B\|KIF5A\|LARS2\|LETM1\|LMBRD1\|LRPPRC\|MAOA\|MAPT\|MARS2\|MCCC1\|MCCC2\|ME2\|MECP2\|MFN2\|MFSD8\|MGAT2\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MPV17\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|MYH7\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA3\|NDUFA4\|NDUFA5\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAB1\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB1\|NDUFB10\|NDUFB11\|NDUFB2\|NDUFB3\|NDUFB4\|NDUFB5\|NDUFB6\|NDUFB7\|NDUFB8\|NDUFB9\|NDUFC1\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NEFL\|NIPA1\|NKX2-1\|NPC1\|NPC2\|NUBPL\|OAT\|OGDH\|OPA1\|OPA3\|OTC\|OXA1L\|OXCT1\|PAFAH1B1\|PANK2\|PARL\|PARS2\|PC\|PCCA\|PCCB\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX13\|PHB\|PHYH\|PLP1\|PMM2\|PNKD\|PNPLA2\|PNPLA3\|POLG\|POLG2\|PPM1B\|PPOX\|PPT1\|PREPL\|PRKCG\|PRODH\|PUS1\|PWAR1\|RARS2\|REEP1\|RFT1\|RMRP\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RRM2B\|RYR1\|SAMHD1\|SARS2\|SCN1A\|SCO1\|SCO2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SGCD\|SLC12A3\|SLC16A2\|SLC19A2\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A16\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC29A3\|SLC2A1\|SLC2A10\|SLC33A1\|SLC35A1\|SLC35C1\|SLC3A1\|SLC52A1\|SLC6A8\|SLC7A9\|SOD1\|SPAST\|SPG11\|SPG20\|SPG7\|SPTBN2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TACO1\|TARS2\|TAZ\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOP1MT\|TPM2\|TPP1\|TRMU\|TSFM\|TTBK2\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCR10\|UQCR11\|UQCRB\|UQCRC1\|UQCRC2\|UQCRFS1\|UQCRH\|UQCRQ\|UROS\|USMG5\|VARS2\|WARS2\|WFS1\|XDH\|XPNPEP3\|YARS2\|ZFYVE26 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000509336.2 | Transgenomic Transgenomic Connecticut 07D0995237 509336 | ABAT\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDK\|BCS1L\|BRAF\|BTD\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCDC88C\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX10\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EOMES\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LRPPRC\|MAGI2\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFAF6\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHLRC1\|NIPBL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RBFOX1\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC4A10\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|STIL\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VDAC1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000305775.2 | UW Cytogenetic Services University of Wisconsin - Madison/WSLH Wisconsin 52D0669558 305775 | Sex chromosome X | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis | Fluorescence In Situ Hybridization\|Fluorescence In Situ Hybridization\|Microarray | Peripheral (whole) blood | Decline to answer | Yes

Table D-3 Genetic tests for Developmental Delay

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Gene | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000323171.3 | (AC) Atlanta Center: Medical Neurogenetics, LLC. Georgia 11D0703390 323171 | GFER | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Skin\|White blood cell prep | Decline to answer | Yes
GTR000508280.2 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 508280 | AARS2\|AASS\|ABAT\|ABCA12\|ABCA4\|ABCB11\|ABCB4\|ABCB6\|ABCB7\|ABCD1\|ABHD12\|ABHD5\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACO2\|ACOX1\|ACSF3\|ACSL4\|ADAM9\|ADCK3\|ADSL\|AFG3L2\|AGK\|AGL\|AGPS\|AGXT\|AIFM1\|AIPL1\|AK1\|AK2\|AKAP10\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|ALDOA\|ALDOB\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ALMS1\|AMACR\|AMER1\|AMN\|AMT\|ANKH\|ANKRD26\|AP3B1\|APP\|APTX\|ARG1\|ARL6\|ASL\|ASS1\|ATIC\|ATP5E\|ATP6V0A2\|ATP7A\|ATP7B\|ATP8B1\|ATPAF2\|AUH\|B4GALT1\|B4GALT7\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BCKDHA\|BCKDHB\|BCOR\|BCS1L\|BEST1\|BLOC1S3\|BOLA3\|BRCA1\|BTD\|C10orf2\|C12orf65\|C1QTNF5\|C2orf71\|C8orf37\|CA2\|CA4\|CABP4\|CACNA1F\|CACNA2D4\|CASP8\|CAT\|CBS\|CC2D2A\|CCDC28B\|CCDC39\|CDH23\|CDHR1\|CEP290\|CERKL\|CHAT\|CHM\|CISD2\|CLCN7\|CLN3\|CLRN1\|CNGA1\|CNGA3\|CNGB1\|CNGB3\|COG1\|COG7\|COG8\|COL1A1\|COL1A2\|COL2A1\|COL3A1\|COL5A1\|COL5A2\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|CPOX\|CPS1\|CPT1A\|CPT2\|CRB1\|CRTAP\|CRX\|CRYAB\|CTSA\|CTSD\|CTSK\|CUBN\|CYB5A\|CYB5R3\|CYBA\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP17A1\|CYP1B1\|CYP24A1\|CYP27A1\|CYP27B1\|CYP4V2\|D2HGDH\|DARS2\|DBT\|DDOST\|DFNB31\|DGUOK\|DHDDS\|DHODH\|DIABLO\|DLAT\|DLD\|DMGDH\|DNAJC19\|DNM1L\|DPM1\|DPM3\|DSP\|DTNBP1\|EFEMP1\|ELAC2\|ELN\|ELOVL4\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|EYA1\|EYA4\|EYS\|FAH\|FAM161A\|FAM20C\|FASTKD2\|FBLN5\|FBN1\|FBP1\|FECH\|FH\|FKBP10\|FLVCR1\|FOXC1\|FOXL2\|FOXRED1\|FRMD7\|FSCN2\|FXN\|FYCO1\|FZD4\|G6PC\|GAA\|GAD1\|GALC\|GALE\|GALK1\|GALNS\|GALT\|GAMT\|GARS\|GATM\|GBE1\|GCDH\|GCK\|GCKR\|GCSH\|GFER\|GFM1\|GIF\|GJA3\|GK\|GLB1\|GLDC\|GLRX5\|GLUD1\|GLYCTK\|GM2A\|GNAT1\|GNAT2\|GNE\|GNPTAB\|GNS\|GOT1\|GPD1\|GPD2\|GPI\|GPR143\|GPR98\|GPX1\|GRK1\|GRM6\|GRN\|GSN\|GUCA1A\|GUCA1B\|GUCY2D\|GUSB\|GYS1\|GYS2\|HADHA\|HADHB\|HAGH\|HARS\|HAX1\|HBB\|HCCS\|HESX1\|HEXA\|HEXB\|HGSNAT\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HNF1A\|HNF1B\|HP\|HPRT1\|HPS1\|HPS3\|HPS4\|HPS5\|HPS6\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH2\|IDH3B\|IMPDH1\|IMPG2\|INPP5E\|INVS\|IQCB1\|ISCU\|IVD\|JAG1\|KARS\|KCNJ13\|KCNV2\|KIF1B\|KIF21A\|KLHL7\|KRT12\|KRT3\|KRT5\|L2HGDH\|LCA5\|LDHA\|LDHB\|LEMD3\|LEPRE1\|LIAS\|LMBRD1\|LMX1B\|LPIN1\|LRAT\|LRP5\|LRPPRC\|MAN2B1\|MANBA\|MAOA\|MC1R\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MEF2A\|MEN1\|MERTK\|MFN2\|MFRP\|MGAT2\|MKKS\|MKS1\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MPDU1\|MPI\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MSRB3\|MTHFR\|MTO1\|MTPAP\|MTR\|MTRR\|MUT\|MUTYH\|MYO7A\|MYOC\|NAGLU\|NAGS\|NCOA4\|NDP\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NEFH\|NEUROD1\|NFU1\|NHS\|NME1\|NPHP1\|NPHP3\|NPHP4\|NRL\|NT5C3A\|NUBPL\|NYX\|OAT\|OCA2\|OCRL\|OGDH\|OGG1\|OPA1\|OPA3\|OPN1LW\|OPN1MW\|OPTN\|OSTM1\|OTC\|OTX2\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PAX2\|PAX6\|PC\|PCCA\|PCCB\|PCDH15\|PCK2\|PDE6A\|PDE6B\|PDE6C\|PDE6G\|PDHA1\|PDHB\|PDP1\|PDSS1\|PDSS2\|PDZD7\|PFKM\|PGAM2\|PGM1\|PHB\|PHKA1\|PHKA2\|PHKB\|PHKG2\|PHOX2A\|PHYH\|PINK1\|PITPNM3\|PITX2\|PITX3\|PLA2G2A\|PLOD2\|PLOD3\|PMM2\|PNKD\|PNPLA2\|POLG\|POLG2\|PPARG\|PPARGC1B\|PPIB\|PPOX\|PPP2R1B\|PRCD\|PRKCG\|PRODH\|PROM1\|PRPF31\|PRPF6\|PRPF8\|PRPH2\|PSAP\|PSEN1\|PTRF\|PTS\|PUS1\|PYCR1\|PYGL\|PYGM\|QDPR\|RAF1\|RARS2\|RAX\|RB1\|RD3\|RDH12\|RDH5\|REEP1\|RET\|RFT1\|RGR\|RGS9\|RHO\|RILP\|RIMS1\|RLBP1\|RNASEL\|RP1\|RP1L1\|RP2\|RP9\|RPE65\|RPGR\|RPGRIP1\|RPL35A\|RPS14\|RRM2B\|RS1\|SAG\|SARDH\|SARS2\|SCO2\|SCP2\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SECISBP2\|SEMA4A\|SEPT9\|SERPINF1\|SGSH\|SHH\|SIX6\|SLC16A1\|SLC22A4\|SLC22A5\|SLC24A1\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC26A4\|SLC34A1\|SLC35A1\|SLC35C1\|SLC37A4\|SLC39A13\|SLC3A1\|SLC45A2\|SLC9A3R1\|SLC9A6\|SMPD1\|SNCB\|SNRNP200\|SOD1\|SOD2\|SOST\|SOX2\|SP7\|SPATA7\|SPG7\|SPR\|SPTLC2\|SQSTM1\|SRD5A3\|STAR\|STAT1\|STAT3\|STRA6\|STXBP1\|SUCLA2\|SUCLG1\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TCN2\|TEAD1\|TGFB1\|TGFBI\|TIMM8A\|TIMP3\|TK2\|TLR3\|TLR4\|TMEM126A\|TMEM127\|TMEM67\|TMEM70\|TNFRSF11A\|TNFRSF11B\|TNFSF11\|TOPORS\|TP53\|TPP1\|TRIM32\|TRMU\|TRPM1\|TSFM\|TSPAN12\|TTC19\|TTC8\|TUBA1A\|TUBB3\|TUFM\|TULP1\|TUSC3\|TYMP\|TYR\|TYROBP\|TYRP1\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|USH1C\|USH1G\|USH2A\|VCP\|VHL\|VSX1\|WFS1\|WT1\|WWOX\|XDH\|XPNPEP3\|YARS2\|ZEB1\|ZFHX3\|ZNF513 | Deletion/duplication analysis | Comparative Genomic Hybridization | — | Not reported | Not reported
GTR000295241.1 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 295241 | Human genome | Detection of homozygosity\|Detection of homozygosity | SNP Detection\|SNP Detection | Amniocytes\|Amniotic fluid\|Bone marrow\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fetal blood\|Fibroblasts\|Isolated DNA\|Product of conception (POC)\|Saliva\|Skin | Decline to answer | No
GTR000500252.2 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 500252 | Human genome | Deletion/duplication analysis | Microarray | Amniocytes\|Amniotic fluid\|Bone marrow\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000500030.2 | Clinical Molecular Genetics Diagnostic Laboratory University of Miami Miller School of Medicine Florida 10D2024894 500030 | Human genome | Deletion/duplication analysis | Microarray | Peripheral (whole) blood | Yes (Pre-test), Decline to Answer (Post-test) | Yes
GTR000500936.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500936 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|C21orf33\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|G6PD\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|HTT\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000503671.2 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 503671 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000500620.3 | Cytogenetics and Microarray Laboratory Kennedy Krieger Institute Maryland 21D0649789 500620 | Human genome | Deletion/duplication analysis | Microarray | Cord blood\|Fetal blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000316021.1 | Cytogenetics and Molecular Pathology Laboratory DLP Marquette General Hospital, LLC Michigan 23D1062707 316021 | CTNND2 | FISH-interphase\|FISH-metaphase\|Karyotyping | Fluorescent in situ Hybridization\|Fluorescent in situ Hybridization\|G-banding | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Peripheral (whole) blood | Yes | No
GTR000167401.2 | DNA Diagnostic Laboratory at Johns Hopkins Johns Hopkins Hospital Maryland 21D0692357 167401 | FGFR3 | Sequence analysis of select exons | Bi-directional Sanger Sequence Analysis | — | Decline to answer | Yes
GTR000501810.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501810 | Human genome | Karyotyping | Microarray | Cord blood\|Dried blood spot (DBS) card\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000501811.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501811 | Human genome | Karyotyping | Microarray | Cord blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood | No | No
GTR000509392.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509392 | ABCC8\|ALMS1\|ARL6\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BDNF\|CEL\|CEP290\|EIF2AK3\|FOXP3\|GCK\|GLIS3\|GNAS\|HNF1A\|HNF1B\|HNF4A\|INS\|KCNJ11\|LEP\|LEPR\|MAGEL2\|MC4R\|MKKS\|MKS1\|NEUROD1\|NEUROG3\|NTRK2\|PCSK1\|PDX1\|POMC\|PTF1A\|RFX6\|SDCCAG8\|SIM1\|TRIM32\|TTC8\|WDPCP\|WFS1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509442.11 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509442 | ABCC6\|ABCD1\|ABCG5\|ACAT1\|ACOX1\|ACSL4\|ACY1\|ADAR\|ADSL\|AFF2\|AFP\|AGL\|AGT\|AGTR2\|AHI1\|AIFM1\|ALDH18A1\|ALDH4A1\|ALG11\|ALG12\|ALG6\|ALX4\|AMER1\|AP1S1\|AP1S2\|AP3B1\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|APOB\|AQP7\|AR\|ARG1\|ARHGEF6\|ARID1A\|ARID1B\|ARX\|ASPM\|ASS1\|ATL1\|ATM\|ATP13A2\|ATP1A2\|ATP6AP2\|ATP7A\|ATRX\|AUH\|AVP\|AVPR2\|BBS9\|BCS1L\|BIN1\|BRCA2\|BRIP1\|BRWD3\|BUB1B\|CACNG2\|CAMTA1\|CANT1\|CASK\|CBS\|CC2D1A\|CC2D2A\|CCDC88C\|CDH15\|CDKL5\|CDKN1C\|CEP290\|CEP41\|CEP57\|CHD7\|CHRNA4\|CLN3\|CNTNAP2\|COG5\|COG7\|COL1A2\|CP\|CPA6\|CPS1\|CRADD\|CRBN\|CTC1\|CTNNB1\|CTSA\|CUL4B\|CYB5R3\|CYP27A1\|D2HGDH\|DARS2\|DBT\|DHCR24\|DHCR7\|DIP2B\|DLG3\|DMD\|DPYD\|DYNC1H1\|DYRK1A\|EBP\|EFNB1\|EHMT1\|ELOVL4\|ERCC2\|ERCC3\|ERCC5\|ERCC6\|ERCC8\|F5\|FAM126A\|FANCG\|FBLN5\|FBN1\|FBN2\|FGD1\|FGF14\|FGFR1\|FGFR2\|FGFR3\|FKRP\|FKTN\|FMR1\|FOXG1\|FOXP1\|FTO\|FTSJ1\|G6PC3\|GABRG2\|GALE\|GAMT\|GAN\|GBA\|GBE1\|GCK\|GDI1\|GFAP\|GFM1\|GHR\|GLI3\|GLRA1\|GLUL\|GLYCTK\|GM2A\|GNAS\|GNPAT\|GNPTAB\|GNPTG\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|GRM1\|GSS\|GUSB\|GYS2\|HAX1\|HDAC4\|HDAC8\|HEPACAM\|HEXB\|HOXD10\|HPD\|HSD17B10\|HSPD1\|HUWE1\|IDS\|IGBP1\|IGF1\|IGF1R\|IL1RAPL1\|INSR\|IQSEC2\|IRX5\|ITGA7\|KCNJ10\|KCNJ11\|KCNK9\|KCNQ2\|KCTD7\|KDM5C\|KIF11\|KIF1A\|KIF21A\|KIF5A\|KIF7\|KIRREL3\|KRAS\|L1CAM\|LAMA2\|LAMP2\|LARGE\|LBR\|LHX3\|LIG4\|LMBRD1\|LRP5\|LYST\|MAGT1\|MAN1B1\|MAN2B1\|MANBA\|MAPT\|MAT1A\|MBD5\|MBTPS2\|MCCC1\|MCCC2\|MCOLN1\|MCPH1\|MECP2\|MED17\|MED23\|MEF2C\|MFSD8\|MGAT2\|MKKS\|MMADHC\|MOCS2\|MPI\|MPZ\|MRAP\|MTFMT\|MTHFR\|MTR\|MYCN\|MYO5A\|MYO7A\|NAGA\|NBN\|NDP\|NDUFA1\|NDUFAF5\|NDUFS1\|NF1\|NGF\|NHEJ1\|NHP2\|NIPBL\|NLGN3\|NPC1\|NPC2\|NPHP3\|NRXN1\|NSDHL\|NSUN2\|OFD1\|OPHN1\|ORC1\|PAFAH1B1\|PAH\|PAK3\|PAX6\|PCDH19\|PCNT\|PDE4D\|PDHX\|PDSS1\|PEX7\|PGK1\|PHF8\|PHKA2\|PHKG2\|PIGL\|PIGO\|PIGV\|PLA2G6\|PLP1\|POMGNT1\|POMT1\|POMT2\|POU1F1\|PPOX\|PQBP1\|PRICKLE1\|PRKAR1A\|PRSS12\|PTEN\|PTPN11\|PYCR1\|PYGL\|RAB39B\|RAB40AL\|RAI1\|RAPSN\|RBBP8\|RBM10\|RFX6\|RPGRIP1L\|RPS6KA3\|SACS\|SAMHD1\|SATB2\|SCN1A\|SCN8A\|SDCCAG8\|SGCA\|SGSH\|SHANK2\|SHANK3\|SHROOM4\|SIL1\|SLC16A2\|SLC20A2\|SLC25A12\|SLC25A13\|SLC25A15\|SLC2A1\|SLC2A2\|SLC35C1\|SLC46A1\|SLC4A4\|SLC5A2\|SLC5A5\|SLC6A4\|SLC6A8\|SLC7A7\|SLC9A6\|SLX4\|SMARCA4\|SMARCB1\|SMC1A\|SMS\|SNIP1\|SOBP\|SOX10\|SOX2\|SOX3\|SPR\|SPTAN1\|SPTLC1\|SRD5A3\|SRPX2\|ST3GAL3\|STAT5B\|STRA6\|STX11\|STXBP1\|SUCLG1\|SYNGAP1\|SYP\|SYT14\|TBC1D24\|TBCE\|TBX1\|TECR\|TGIF1\|TH\|THRB\|TINF2\|TMCO1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPH2\|TPK1\|TRAPPC9\|TRHR\|TSC1\|TSC2\|TSHR\|TSPAN7\|TTC37\|TTR\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|TUSC3\|TWIST1\|UBE2A\|UBE3A\|UPB1\|UPF3B\|UROC1\|USP9X\|VLDLR\|VPS13B\|WDR62\|WDR81\|WRN\|XIST\|XPNPEP3\|ZBTB16\|ZBTB24\|ZDHHC9\|ZEB2\|ZFP57\|ZFYVE26\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | — | Not reported | Not reported
GTR000510915.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510915 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ABCD3\|ACACA\|ACACB\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACLY\|ACO2\|ACSF3\|ACSL4\|ACSL5\|ACSM3\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AGXT2\|AIFM1\|AK2\|AKAP10\|AKR7A2\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|AS3MT\|ASS1\|ATIC\|ATP10D\|ATP5E\|ATP5SL\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BAX\|BCAT1\|BCAT2\|BCKDHA\|BCKDHB\|BCL2\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDC42BPB\|CDKL5\|CFTR\|CHAT\|CHDH\|CHRNA4\|CHRNB2\|CISD2\|CKM\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CLYBL\|CNR1\|COA5\|COMT\|COQ2\|COQ4\|COQ5\|COQ6\|COQ9\|COX10\|COX15\|COX4I1\|COX4I2\|COX6B1\|COX7A2\|CPOX\|CPS1\|CPT1A\|CPT1B\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDAH1\|DDC\|DECR1\|DGUOK\|DHODH\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNAJC5\|DNM1L\|DTNBP1\|EARS2\|ECI1\|ECSIT\|ELAC2\|ELN\|ENO1\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FAAH\|FARS2\|FASN\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FPGS\|FTH1\|FXN\|G6PC\|G6PD\|GAD1\|GAD2\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLO1\|GLRA1\|GLRX5\|GLS\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPAM\|GPD1\|GPD2\|GPI\|GPX1\|GPX4\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HARS\|HARS2\|HCCS\|HIBCH\|HIGD2A\|HK1\|HK2\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B1\|HSD3B2\|HSPA9\|HSPB7\|HSPD1\|HTRA2\|HTT\|IDE\|IDH1\|IDH2\|IDH3B\|IMMP2L\|IMMT\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|KYNU\|L2HGDH\|LARS2\|LDHA\|LDHB\|LETM1\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MAOB\|MARS2\|MAVS\|MCCC1\|MCCC2\|MCEE\|MDH1\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MGLL\|MGST3\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCOS\|MOCS1\|MOCS2\|MOGS\|MRPL3\|MRPL48\|MRPS16\|MRPS22\|MRRF\|MTCH2\|MTFMT\|MTHFD1\|MTHFD1L\|MTHFS\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA4\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB1\|NDUFB3\|NDUFB6\|NDUFB9\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NFU1\|NIPSNAP1\|NIPSNAP3A\|NLRX1\|NME1\|NOS3\|NPL\|NRXN1\|NTHL1\|NUBPL\|OAT\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PACRG\|PAH\|PAK7\|PANK2\|PARK2\|PARL\|PARP1\|PC\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PKLR\|PMPCA\|PNKD\|PNMT\|POLG\|POLG2\|POLRMT\|PPARGC1A\|PPARGC1B\|PPOX\|PPT1\|PREPL\|PRODH\|PTGES2\|PTS\|PUS1\|PYCR1\|QDPR\|RAB11FIP5\|RARS2\|REEP1\|RNASEL\|RPL35A\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SHMT1\|SIRT1\|SIRT3\|SIRT5\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A39\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|TACO1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TFAM\|TFB1M\|TIMM44\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOMM40\|TOP1MT\|TP53\|TPH2\|TPI1\|TPP1\|TRMU\|TSFM\|TSPO\|TST\|TTC19\|TUFM\|TXN2\|TXNRD2\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|USP24\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000515046.3 | Illumina Clinical Services Laboratory Illumina California 05D1092911 515046 | — | — | — | — | Not reported | Not reported
GTR000510735.1 | Insight Medical Genetics Insight Medical Genetics Illinois 14D1000956 510735 | ALPL\|COL2A1\|ESCO2\|FGFR2\|FGFR3\|ROR2\|SLC26A2\|SOX9 | Mutation scanning of select exons | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | No
GTR000501388.2 | Lineagen, Inc Utah 46D2042721 501388 | Human genome | Deletion/duplication analysis | Microarray | Buccal swab\|Peripheral (whole) blood | No | Yes
GTR000500624.2 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500624 | FMR1 | Targeted variant analysis | PCR with allele specific hybridization | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Dried blood spot (DBS) card\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Serum\|Skin | No | No
GTR000500513.1 | Mount Sinai Genetic Testing Laboratory Icahn School of Medicine at Mount Sinai New York 33D0653419 500513 | Human genome | Karyotyping | Microarray | Fetal blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Please visit http://www.mssm.edu/genetictesting for test specifi\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin | Yes (Pre-test), Decline to Answer (Post-Test) | Yes
GTR000504341.2 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 504341 | Human genome | Deletion/duplication analysis | Microarray\|SNP Detection | Cord blood\|Peripheral (whole) blood | No | Yes
GTR000504346.1 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 504346 | Human genome | Karyotyping\|Deletion/duplication analysis | G-banding\|Microarray\|SNP Detection | Peripheral (whole) blood | No | Yes
GTR000504349.1 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 504349 | Human genome | Karyotyping\|Deletion/duplication analysis | G-banding\|Microarray\|SNP Detection | Peripheral (whole) blood | No | Yes
GTR000506028.2 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 506028 | Human genome | Deletion/duplication analysis | Microarray\|SNP Detection | Cord blood\|Peripheral (whole) blood | No | Yes
GTR000506033.2 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 506033 | Human genome | Karyotyping\|Deletion/duplication analysis | G-banding\|Microarray\|SNP Detection | Peripheral (whole) blood | No | Yes
GTR000506036.2 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 506036 | Human genome | Karyotyping\|Deletion/duplication analysis | G-banding\|Microarray\|SNP Detection | Peripheral (whole) blood | No | Yes
GTR000501919.2 | Transgenomic Transgenomic Connecticut 07D0995237 501919 | AARS2\|AASS\|ABAT\|ABCB7\|ABCD1\|ABHD5\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADSB\|ACADVL\|ACAT1\|ACSF3\|ACSL4\|ADCK3\|AFG3L2\|AGXT\|AIFM1\|AIFM2\|AK2\|AKR1D1\|ALAS2\|ALDH18A1\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMACR\|AMT\|APEX2\|APTX\|ARG1\|ARMS2\|ASL\|ASS1\|ATL1\|ATM\|ATP5A1\|ATP5B\|ATP5C1\|ATP5D\|ATP5E\|ATP5F1\|ATP5G1\|ATP5G2\|ATP5G3\|ATP5I\|ATP5J\|ATP5O\|ATP7B\|ATPAF1\|ATPAF2\|ATPIF1\|ATXN10\|ATXN7\|AUH\|B4GALT1\|BCKDHA\|BCKDHB\|BCS1L\|BRAF\|BTD\|C10orf2\|C12orf65\|C14orf2\|CAPN3\|CARS2\|CAV3\|CDKL5\|CHKB\|CISD2\|CLN3\|CLN5\|CLN6\|CLN8\|CMC1\|COG1\|COG7\|COG8\|COQ2\|COQ3\|COQ4\|COQ6\|COQ7\|COQ9\|COX10\|COX11\|COX15\|COX17\|COX18\|COX19\|COX4I1\|COX4I2\|COX5A\|COX5B\|COX6A1\|COX6A2\|COX6B1\|COX6C\|COX7A1\|COX7A2\|COX7A2L\|COX7B\|COX7B2\|COX7C\|COX8A\|CPOX\|CPS1\|CPT1A\|CPT2\|CRLS1\|CRYAB\|CTNS\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYC1\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP27A1\|CYP27B1\|CYP7B1\|D2HGDH\|DARS2\|DBT\|DCX\|DECR1\|DGUOK\|DLAT\|DLD\|DLST\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DNM2\|DOLK\|DPAGT1\|DPM1\|DPM3\|EARS2\|ECSIT\|EIF2AK3\|ELOVL4\|ETFA\|ETFB\|ETFDH\|ETHE1\|FA2H\|FARS2\|FASTKD2\|FECH\|FGF14\|FH\|FOXG1\|FOXRED1\|FXN\|GAA\|GAD1\|GAMT\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLA\|GLDC\|GLRX5\|GLUD1\|GNPAT\|GPD2\|GPHN\|HADH\|HADHA\|HADHB\|HARS2\|HAX1\|HCCS\|HFE\|HK1\|HLCS\|HMGCL\|HMGCS2\|HSD17B10\|HSD3B2\|HSPD1\|IARS2\|IDH2\|ISCU\|ITPR1\|IVD\|KARS\|KCNC3\|KCNJ11\|KIAA0196\|KIAA0226\|KIF1B\|KIF5A\|LARS2\|LETM1\|LMBRD1\|LRPPRC\|MAOA\|MAPT\|MARS2\|MCCC1\|MCCC2\|ME2\|MECP2\|MFN2\|MFSD8\|MGAT2\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MPV17\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|MYH7\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA3\|NDUFA4\|NDUFA5\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAB1\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB1\|NDUFB10\|NDUFB11\|NDUFB2\|NDUFB3\|NDUFB4\|NDUFB5\|NDUFB6\|NDUFB7\|NDUFB8\|NDUFB9\|NDUFC1\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NEFL\|NIPA1\|NKX2-1\|NPC1\|NPC2\|NUBPL\|OAT\|OGDH\|OPA1\|OPA3\|OTC\|OXA1L\|OXCT1\|PAFAH1B1\|PANK2\|PARL\|PARS2\|PC\|PCCA\|PCCB\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX13\|PHB\|PHYH\|PLP1\|PMM2\|PNKD\|PNPLA2\|PNPLA3\|POLG\|POLG2\|PPM1B\|PPOX\|PPT1\|PREPL\|PRKCG\|PRODH\|PUS1\|PWAR1\|RARS2\|REEP1\|RFT1\|RMRP\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RRM2B\|RYR1\|SAMHD1\|SARS2\|SCN1A\|SCO1\|SCO2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SGCD\|SLC12A3\|SLC16A2\|SLC19A2\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A16\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC29A3\|SLC2A1\|SLC2A10\|SLC33A1\|SLC35A1\|SLC35C1\|SLC3A1\|SLC52A1\|SLC6A8\|SLC7A9\|SOD1\|SPAST\|SPG11\|SPG20\|SPG7\|SPTBN2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TACO1\|TARS2\|TAZ\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOP1MT\|TPM2\|TPP1\|TRMU\|TSFM\|TTBK2\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCR10\|UQCR11\|UQCRB\|UQCRC1\|UQCRC2\|UQCRFS1\|UQCRH\|UQCRQ\|UROS\|USMG5\|VARS2\|WARS2\|WFS1\|XDH\|XPNPEP3\|YARS2\|ZFYVE26 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000322598.2 | Ambry Genetics Ambry Genetics California 05D0981414 322598 | FMR1 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood | Decline to answer (pre-test), No (post-test) | Yes
GTR000500911.4 | Asuragen Clinical Laboratory Asuragen, Inc Texas 45D1069375 500911 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Buccal swab\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000510864.2 | Asuragen Clinical Laboratory Asuragen, Inc Texas 45D1069375 510864 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Buccal swab\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000505885.2 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 505885 | FMR1 | Methylation analysis | PCR-RFLP with Southern hybridization | Peripheral (whole) blood | No | No
GTR000511954.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511954 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | Not reported | No
GTR000511955.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511955 | FMR1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000511956.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511956 | FMR1 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000511957.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511957 | FMR1 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000511965.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511965 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | Not reported | No
GTR000502891.1 | Center for Genetics at Saint Francis Saint Francis Hospital Oklahoma 37D0474681 502891 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000006798.1 | Center for Human Genetics Laboratory University Hospitals - University Hospitals Laboratory Service Foundation Ohio 36D0656024 6798 | FMR1 | Targeted variant analysis | PCR-RFLP with Southern hybridization | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000004006.1 | Center for Human Genetics, Inc Massachusetts 22D0650242 4006 | FMR1 | Methylation analysis\|Targeted variant analysis | Methylation-specific PCR\|Trinucleotide repeat by PCR or Southern Blot | Not reported | Decline to answer | No
GTR000004082.1 | Clinical Molecular Genetics Laboratory All Children’s Hospital Florida 10D0700790 4082 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Buccal swab\|Chorionic villi\|Fibroblasts\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501051.2 | Counsyl California 05D1102604 501051 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000503904.1 | Cytogenetics and Molecular Genetics Laboratory Mercy St. Vincent Medical Center Ohio 36D0965797 503904 | FMR1 | Microsatellite instability testing (MSI) | Trinucleotide repeat by PCR or Southern Blot | Peripheral (whole) blood | Decline to answer | Yes
GTR000501519.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501519 | FMR1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501520.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501520 | FMR1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501753.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501753 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | No | No
GTR000503266.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503266 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | No | No
GTR000503286.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503286 | FMR1, Human Genome | Analyte\|Karyotyping\|Targeted variant analysis | Dimethylene Blue binding Quantitation and Thin Layer Chromatography\|GC-MS/MS\|Ion-Exchange Chromatography\|Isotope dilution method by LC-MS/MS\|MALDI-TOF/TOF\|Comparative Genomic Hybridization\|Trinucleotide repeat by PCR or Southern Blot | Not reported | No | No
GTR000503288.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503288 | FMR1, Human Genome | Karyotyping\|Targeted variant analysis | Comparative Genomic Hybridization\|Trinucleotide repeat by PCR or Southern Blot | Not reported | No | No
GTR000512586.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512586 | ABCD1\|ACSL4\|AFF2\|AP1S2\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDK16\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|HCCS\|HCFC1\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|KLF8\|L1CAM\|LAMP2\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SYN1\|SYP\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|ZDHHC15\|ZDHHC9\|ZNF711 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512587.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512587 | ADSL\|AFF2\|AP1S2\|ARX\|ATRX\|BCKDK\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DHCR7\|DMD\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|HPRT1\|KDM5C\|L1CAM\|MAGEL2\|MBD5\|MECP2\|MED12\|MEF2C\|MID1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NR1I3\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RELN\|SCN1A\|SLC2A1\|SLC9A6\|SMARCB1\|SMC1A\|TCF4\|UBE2A\|UBE3A\|VPS13B\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000500301.3 | Fragile X Laboratory/IBR Specialty Clinical Laboratories New York State Institute for Basic Research in Developmental Disabilities New York 33D0860102 500301 | FMR1 | Targeted variant analysis | Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Dried blood spot (DBS) card\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|White blood cell prep | No | No
GTR000509342.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509342 | ANKRD11\|AP1S2\|ARX\|ATRX\|AUTS2\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CHD8\|CNTNAP2\|CNTNAP5\|CREBBP\|DHCR7\|DLGAP2\|DMD\|DOCK4\|DPP10\|DPP6\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GABRG1\|GNA14\|GRIN2B\|GRPR\|HOXA1\|HPRT1\|IMMP2L\|KATNAL2\|KCTD13\|KDM5C\|KIRREL3\|KLHL3\|L1CAM\|LAMC3\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|NEGR1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRXN1\|NSD1\|NTNG1\|OPHN1\|PAFAH1B1\|PCDH19\|PCDH9\|PDE10A\|PHF6\|PIP5K1B\|PNKP\|PON3\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RBFOX1\|RELN\|RPL10\|SATB2\|SCN1A\|SCN2A\|SHANK2\|SHANK3\|SLC6A4\|SLC9A6\|SLC9A9\|SMC1A\|SMG6\|SNRPN\|SOX5\|SPAST\|ST7\|STK3\|TCF4\|TSC1\|TSC2\|UBE3A\|VPS13B\|ZEB2\|ZNF507\|ZNF804A\|ZNHIT6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509442.11 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509442 | ABCC6\|ABCD1\|ABCG5\|ACAT1\|ACOX1\|ACSL4\|ACY1\|ADAR\|ADSL\|AFF2\|AFP\|AGL\|AGT\|AGTR2\|AHI1\|AIFM1\|ALDH18A1\|ALDH4A1\|ALG11\|ALG12\|ALG6\|ALX4\|AMER1\|AP1S1\|AP1S2\|AP3B1\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|APOB\|AQP7\|AR\|ARG1\|ARHGEF6\|ARID1A\|ARID1B\|ARX\|ASPM\|ASS1\|ATL1\|ATM\|ATP13A2\|ATP1A2\|ATP6AP2\|ATP7A\|ATRX\|AUH\|AVP\|AVPR2\|BBS9\|BCS1L\|BIN1\|BRCA2\|BRIP1\|BRWD3\|BUB1B\|CACNG2\|CAMTA1\|CANT1\|CASK\|CBS\|CC2D1A\|CC2D2A\|CCDC88C\|CDH15\|CDKL5\|CDKN1C\|CEP290\|CEP41\|CEP57\|CHD7\|CHRNA4\|CLN3\|CNTNAP2\|COG5\|COG7\|COL1A2\|CP\|CPA6\|CPS1\|CRADD\|CRBN\|CTC1\|CTNNB1\|CTSA\|CUL4B\|CYB5R3\|CYP27A1\|D2HGDH\|DARS2\|DBT\|DHCR24\|DHCR7\|DIP2B\|DLG3\|DMD\|DPYD\|DYNC1H1\|DYRK1A\|EBP\|EFNB1\|EHMT1\|ELOVL4\|ERCC2\|ERCC3\|ERCC5\|ERCC6\|ERCC8\|F5\|FAM126A\|FANCG\|FBLN5\|FBN1\|FBN2\|FGD1\|FGF14\|FGFR1\|FGFR2\|FGFR3\|FKRP\|FKTN\|FMR1\|FOXG1\|FOXP1\|FTO\|FTSJ1\|G6PC3\|GABRG2\|GALE\|GAMT\|GAN\|GBA\|GBE1\|GCK\|GDI1\|GFAP\|GFM1\|GHR\|GLI3\|GLRA1\|GLUL\|GLYCTK\|GM2A\|GNAS\|GNPAT\|GNPTAB\|GNPTG\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|GRM1\|GSS\|GUSB\|GYS2\|HAX1\|HDAC4\|HDAC8\|HEPACAM\|HEXB\|HOXD10\|HPD\|HSD17B10\|HSPD1\|HUWE1\|IDS\|IGBP1\|IGF1\|IGF1R\|IL1RAPL1\|INSR\|IQSEC2\|IRX5\|ITGA7\|KCNJ10\|KCNJ11\|KCNK9\|KCNQ2\|KCTD7\|KDM5C\|KIF11\|KIF1A\|KIF21A\|KIF5A\|KIF7\|KIRREL3\|KRAS\|L1CAM\|LAMA2\|LAMP2\|LARGE\|LBR\|LHX3\|LIG4\|LMBRD1\|LRP5\|LYST\|MAGT1\|MAN1B1\|MAN2B1\|MANBA\|MAPT\|MAT1A\|MBD5\|MBTPS2\|MCCC1\|MCCC2\|MCOLN1\|MCPH1\|MECP2\|MED17\|MED23\|MEF2C\|MFSD8\|MGAT2\|MKKS\|MMADHC\|MOCS2\|MPI\|MPZ\|MRAP\|MTFMT\|MTHFR\|MTR\|MYCN\|MYO5A\|MYO7A\|NAGA\|NBN\|NDP\|NDUFA1\|NDUFAF5\|NDUFS1\|NF1\|NGF\|NHEJ1\|NHP2\|NIPBL\|NLGN3\|NPC1\|NPC2\|NPHP3\|NRXN1\|NSDHL\|NSUN2\|OFD1\|OPHN1\|ORC1\|PAFAH1B1\|PAH\|PAK3\|PAX6\|PCDH19\|PCNT\|PDE4D\|PDHX\|PDSS1\|PEX7\|PGK1\|PHF8\|PHKA2\|PHKG2\|PIGL\|PIGO\|PIGV\|PLA2G6\|PLP1\|POMGNT1\|POMT1\|POMT2\|POU1F1\|PPOX\|PQBP1\|PRICKLE1\|PRKAR1A\|PRSS12\|PTEN\|PTPN11\|PYCR1\|PYGL\|RAB39B\|RAB40AL\|RAI1\|RAPSN\|RBBP8\|RBM10\|RFX6\|RPGRIP1L\|RPS6KA3\|SACS\|SAMHD1\|SATB2\|SCN1A\|SCN8A\|SDCCAG8\|SGCA\|SGSH\|SHANK2\|SHANK3\|SHROOM4\|SIL1\|SLC16A2\|SLC20A2\|SLC25A12\|SLC25A13\|SLC25A15\|SLC2A1\|SLC2A2\|SLC35C1\|SLC46A1\|SLC4A4\|SLC5A2\|SLC5A5\|SLC6A4\|SLC6A8\|SLC7A7\|SLC9A6\|SLX4\|SMARCA4\|SMARCB1\|SMC1A\|SMS\|SNIP1\|SOBP\|SOX10\|SOX2\|SOX3\|SPR\|SPTAN1\|SPTLC1\|SRD5A3\|SRPX2\|ST3GAL3\|STAT5B\|STRA6\|STX11\|STXBP1\|SUCLG1\|SYNGAP1\|SYP\|SYT14\|TBC1D24\|TBCE\|TBX1\|TECR\|TGIF1\|TH\|THRB\|TINF2\|TMCO1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPH2\|TPK1\|TRAPPC9\|TRHR\|TSC1\|TSC2\|TSHR\|TSPAN7\|TTC37\|TTR\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|TUSC3\|TWIST1\|UBE2A\|UBE3A\|UPB1\|UPF3B\|UROC1\|USP9X\|VLDLR\|VPS13B\|WDR62\|WDR81\|WRN\|XIST\|XPNPEP3\|ZBTB16\|ZBTB24\|ZDHHC9\|ZEB2\|ZFP57\|ZFYVE26\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab/Isolated DNA/Peripheral (whole) blood/Saliva | Decline to answer | Not reported
GTR000510916.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510916 | ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|AP1S2\|ARHGEF6\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|EBP\|FAAH2\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|GSPT2\|HCCS\|HDAC8\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|L1CAM\|LAMP2\|MAGT1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RAB40AL\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SRPX2\|SYN1\|SYP\|TAF1\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|USP9X\|WDR13\|ZCCHC12\|ZDHHC15\|ZDHHC9\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000511180.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 511180 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Buccal swab\|Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000226645.1 | Genetics Laboratory University of Oklahoma Health Sciences Center Oklahoma 37D0967945 226645 | FMR1 | Targeted variant analysis | PCR-RFLP with Southern hybridization | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000500314.1 | Genetics Laboratory Shodair Children’s Hospital Montana 27D0652530 500314 | FMR1 | Methylation analysis\|Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot\|Trinucleotide repeat by PCR or Southern Blot | Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000500315.2 | Genetics Laboratory Shodair Children’s Hospital Montana 27D0652530 500315 | FMR1 | Methylation analysis\|Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot\|Trinucleotide repeat by PCR or Southern Blot | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000004034.1 | Greenwood Genetic Center Diagnostic Laboratories Greenwood Genetic Center South Carolina 42D0689473 4034 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Saliva\|Skin | Decline to answer | Yes
GTR000327662.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 327662 | AP1S2\|ARX\|ASPM\|ATRX\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CBL\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DCX\|DHCR7\|DMD\|EHMT1\|ERCC6\|ERCC8\|FGD1\|FGFR1\|FGFR2\|FGFR3\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|HDAC8\|HOXA1\|HPRT1\|HRAS\|KDM5C\|KMT2D\|KRAS\|L1CAM\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|MKKS\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCH1\|PTEN\|PTPN11\|RAB39B\|RAD21\|RAF1\|RAI1\|RELN\|RPGRIP1L\|RPS6KA3\|SCN1A\|SHANK2\|SHANK3\|SHOC2\|SLC2A1\|SLC6A4\|SLC9A6\|SMC1A\|SMC3\|SOS1\|SPRED1\|TCF4\|TSC1\|TSC2\|TUBA1A\|UBE3A\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | No | No
GTR000004902.1 | Knight Diagnostic Laboratories - Molecular Diagnostic Center Oregon Health and Science University Oregon 38D0881787 4902 | FMR1 | Methylation analysis\|Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot\|Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000331372.1 | Knight Diagnostic Laboratories - Molecular Diagnostic Center Oregon Health and Science University Oregon 38D0881787 331372 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000005424.4 | Molecular and Biochemical Genetics Laboratory Dayton Children’s Hospital Ohio 36D0859317 5424 | FMR1 | Targeted variant analysis | Southern Blot and PCR | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000005238.1 | Molecular Diagnostic Laboratory Barnes Jewish Hospital Missouri 26D0438670 5238 | FMR1 | Targeted variant analysis | PCR with Fragment Analysis\|PCR-RFLP with Southern hybridization | Peripheral (whole) blood | Decline to answer | Yes
GTR000026021.3 | Molecular Diagnostic Laboratory Nebraska Medical Center Nebraska 28D0453728 26021 | FMR1\|POF1B | Methylation analysis\|Targeted variant analysis | PCR-RFLP with Southern hybridization\|Trinucleotide repeat by PCR or Southern Blot | Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000500327.1 | Molecular Diagnostics Laboratory University of California, San Francisco California 05D1024215 500327 | | Methylation analysis\|Targeted variant analysis | Other\|Trinucleotide repeat by PCR or Southern Blot | Cell culture\|Peripheral (whole) blood | No | Yes
GTR000500334.1 | Molecular Diagnostics Laboratory University of California, San Francisco California 05D1024215 500334 | FMR1 | Methylation analysis\|Targeted variant analysis | Other\|Trinucleotide repeat by PCR or Southern Blot | Cell culture\|Peripheral (whole) blood | No | Yes
GTR000005250.2 | Molecular Genetics Diagnostic Laboratory Detroit Medical Center University Laboratories Michigan 23D0717194 5250 | FMR1 | Methylation analysis\|Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot\|Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Amniotic fluid\|Peripheral (whole) blood | Decline to answer | Yes
GTR000006804.3 | Molecular Genetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 6804 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | Decline to answer | Yes
GTR000203713.1 | Molecular Genetics Laboratory Children’s Mercy Hospital and Clinics Missouri 26D2046586 203713 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000501532.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501532 | FMR1 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000502738.3 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 502738 | FMR1 | Methylation analysis\|Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot\|Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | No | No
GTR000502739.2 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 502739 | FMR1 | Deletion/duplication analysis | Microarray | Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | No | No
GTR000512245.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 512245 | FMR1 | Methylation analysis\|Targeted variant analysis | PCR/Capillary Electrophoresis. Methylation analysis is performed to distinguish between premutation and full mutation alleles.\|PCR/Capillary Electrophoresis. Methylation analysis is performed to distinguish between premutation and full mutation alleles. | Peripheral (whole) blood | Decline to answer | Yes
GTR000512246.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 512246 | FMR1 | Methylation analysis\|Targeted variant analysis | PCR/Capillary Electrophoresis. Methylation analysis is performed to distinguish between premutation and full mutation alleles.\|PCR/Capillary Electrophoresis. Methylation analysis is performed to distinguish between premutation and full mutation alleles. | Amniocytes\|Amniotic fluid\|Cord blood\|Peripheral (whole) blood | Decline to answer | Yes
GTR000004062.1 | Molecular Pathology Laboratory Ohio State University Ohio 36D1080238 4062 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Peripheral (whole) blood | Decline to answer | Yes
GTR000511497.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 511497 | FMR1 | Methylation analysis\|Microsatellite instability testing (MSI) | Methylation-specific PCR\|Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000508090.1 | Quest Diagnostics Nichols Institute San Juan Capistrano — California 05D0643352 508090 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | No | Yes
GTR000508091.1 | Quest Diagnostics Nichols Institute San Juan Capistrano — California 05D0643352 508091 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | No | Yes
GTR000025286.1 | United States Air Force, DNA Diagnostic Laboratory United States Air Force Mississippi — 25286 | FMR1 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Peripheral (whole) blood | No | No
GTR000219909.1 | University of Iowa Diagnostic Laboratories University of Iowa Hospitals and Clinics Iowa 16D0664625 219909 | FMR1 | Methylation analysis\|Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot\|Trinucleotide repeat by PCR or Southern Blot | Cell culture\|Peripheral (whole) blood | Decline to answer | Yes
GTR000305777.1 | UW Cytogenetic Services University of Wisconsin - Madison/WSLH Wisconsin 52D0669558 305777 | FMR1 | Methylation analysis\|Targeted variant analysis | PCR-RFLP with Southern hybridization\|PCR with allele specific hybridization | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes

Table D-5 Genetic tests for Intellectual Disability

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000326450.5 | (AC) Atlanta Center: Medical Neurogenetics, LLC. — Georgia 11D0703390 326450 | FKTN | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Skin\|White blood cell prep | Decline to answer | Yes
GTR000326455.5 | (AC) Atlanta Center: Medical Neurogenetics, LLC. — Georgia 11D0703390 326455 | FKRP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Skin\|White blood cell prep | Decline to answer | Yes
GTR000322643.1 | Ambry Genetics Ambry Genetics California 05D0981414 322643 | BRWD3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322644.1 | Ambry Genetics Ambry Genetics California 05D0981414 322644 | ACSL4 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322645.1 | Ambry Genetics Ambry Genetics California 05D0981414 322645 | AGTR2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322646.1 | Ambry Genetics Ambry Genetics California 05D0981414 322646 | AP1S2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322647.1 | Ambry Genetics Ambry Genetics California 05D0981414 322647 | ARHGEF6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322650.1 | Ambry Genetics Ambry Genetics California 05D0981414 322650 | DLG3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322651.1 | Ambry Genetics Ambry Genetics California 05D0981414 322651 | FTSJ1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322652.1 | Ambry Genetics Ambry Genetics California 05D0981414 322652 | GDI1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322653.1 | Ambry Genetics Ambry Genetics California 05D0981414 322653 | IL1RAPL1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322655.1 | Ambry Genetics Ambry Genetics California 05D0981414 322655 | PAK3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322658.1 | Ambry Genetics Ambry Genetics California 05D0981414 322658 | TSPAN7 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322659.3 | Ambry Genetics Ambry Genetics California 05D0981414 322659 | UPF3B | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000322660.3 | Ambry Genetics Ambry Genetics California 05D0981414 322660 | ZDHHC9 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000322661.1 | Ambry Genetics Ambry Genetics California 05D0981414 322661 | ZNF41 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322666.5 | Ambry Genetics Ambry Genetics California 05D0981414 322666 | CASK | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Cell culture\|Isolated DNA\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000322667.1 | Ambry Genetics Ambry Genetics California 05D0981414 322667 | KDM5C | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322668.2 | Ambry Genetics Ambry Genetics California 05D0981414 322668 | SYP | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322669.1 | Ambry Genetics Ambry Genetics California 05D0981414 322669 | ZNF711 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322670.1 | Ambry Genetics Ambry Genetics California 05D0981414 322670 | ZNF81 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000322720.4 | Ambry Genetics Ambry Genetics California 05D0981414 322720 | CUL4B | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000322721.3 | Ambry Genetics Ambry Genetics California 05D0981414 322721 | FGD1 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000322722.5 | Ambry Genetics Ambry Genetics California 05D0981414 322722 | KIAA2022 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000322723.1 | Ambry Genetics Ambry Genetics California 05D0981414 322723 | ZNF674 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000512790.2 | Athena Diagnostics Inc — Massachusetts 22D0069726 512790 | ARHGEF9\|ARX\|ATP6AP2\|ATRX\|CASK\|CDKL5\|CUL4B\|DCX\|FGD1\|GPC3\|GRIA3\|HSD17B10\|KDM5C\|MECP2\|OFD1\|OPHN1\|PAK3\|PCDH19\|PHF6\|PLP1\|PQBP1\|RAB39B\|SLC9A6\|SMC1A\|SMS\|SRPX2\|SYP | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000512791.2 | Athena Diagnostics Inc — Massachusetts 22D0069726 512791 | ARHGEF9\|ARX\|CDKL5\|CNTNAP2\|FOXG1\|GABRG2\|GRIN2A\|KCNT1\|MECP2\|NRXN1\|PCDH19\|PNKP\|RNASEH2A\|RNASEH2B\|RNASEH2C\|SAMHD1\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|STXBP1\|SYNGAP1\|TCF4\|TREX1\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000512792.2 | Athena Diagnostics Inc — Massachusetts 22D0069726 512792 | ARX\|CDKL5\|FOXG1\|GABRB3\|GRIN2A\|MEF2C\|SCN2A\|SLC25A22\|SPTAN1\|STXBP1 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000512794.2 | Athena Diagnostics Inc — Massachusetts 22D0069726 512794 | ALDH7A1\|CACNA1A\|CASR\|CHRNA2\|CHRNA4\|CHRNB2\|CSTB\|DEPDC5\|EFHC1\|EPM2A\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GRIN2A\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|LGI1\|MBD5\|ME2\|NHLRC1\|PCDH19\|PRICKLE1\|PRICKLE2\|PRRT2\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN9A\|SLC2A1\|SLC4A10\|TBC1D24 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000512795.2 | Athena Diagnostics Inc — Massachusetts 22D0069726 512795 | ARFGEF2\|ARX\|COL18A1\|COL4A1\|CPT2\|DCX\|EMX2\|FGFR3\|FKRP\|FKTN\|FLNA\|GPR56\|LAMA2\|LARGE\|PAFAH1B1\|PAX6\|PEX7\|POMGNT1\|POMT1\|POMT2\|PQBP1\|RAB3GAP1\|RELN\|SNAP29\|SRPX2\|TUBA1A\|TUBA8\|TUBB2B\|WDR62 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000512796.2 | Athena Diagnostics Inc — Massachusetts 22D0069726 512796 | ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATRX\|CACNA1A\|CASK\|CASR\|CCDC88C\|CDKL5\|CHRNA2\|CHRNA4\|CHRNB2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COL18A1\|COL4A1\|CPT2\|CSTB\|CTSD\|CUL4B\|DCX\|DEPDC5\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FGD1\|FGFR3\|FKRP\|FKTN\|FLNA\|FOXG1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GPC3\|GPR56\|GRIA3\|GRIN2A\|HSD17B10\|KCNA1\|KCNJ1\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|LAMA2\|LARGE\|LBR\|LGI1\|MBD5\|ME2\|MECP2\|MEF2C\|MFSD8\|NHLRC1\|NIPBL\|NOTCH3\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PCDH19\|PEX7\|PHF6\|PIGV\|PLA2G6\|PLP1\|PNKP\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRRT2\|RAB39B\|RAB3GAP1\|RAI1\|RELN\|RNASEH2A\|RNASEH2B\|RNASEH2C\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SERPINI1\|SETBP1\|SLC25A22\|SLC2A1\|SLC4A10\|SLC9A6\|SMC1A\|SMC3\|SMS\|SNAP29\|SPTAN1\|SRPX2\|STXBP1\|SYNGAP1\|SYP\|TBC1D24\|TBX1\|TCF4\|TPP1\|TREX1\|TSC1\|TSC2\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VPS13A\|VPS13B\|WDR62\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000512797.2 | Athena Diagnostics Inc — Massachusetts 22D0069726 512797 | ATP2A2\|ATP6V0A2\|CCDC88C\|CLCNKA\|CLCNKB\|KCNA1\|KCNJ1\|KCNJ10\|KIAA1279\|KMT2D\|LBR\|LGI1\|NIPBL\|PANK2\|PIGV\|PLA2G6\|RAI1\|SERPINI1\|SETBP1\|SMC3\|SYNGAP1\|TBX1\|TSC1\|TSC2\|VPS13A\|VPS13B | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000515148.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515148 | ARX | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000515163.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515163 | MEF2C | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000515170.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515170 | SYNGAP1 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000515176.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515176 | ARX | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000515180.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515180 | ARX | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Not reported | No | Yes
GTR000515185.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515185 | MEF2C | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000515191.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515191 | MEF2C | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Not reported | No | Yes
GTR000515218.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515218 | POMT2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515219.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515219 | POMT1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515223.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515223 | FKTN | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515235.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515235 | COL6A1\|COL6A2\|COL6A3\|FKRP\|LAMA2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515238.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515238 | COL6A1\|COL6A2\|COL6A3\|FKRP\|FKTN\|LAMA2\|POMGNT1\|POMT1\|POMT2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515246.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515246 | CAPN3\|CAV3\|DMD\|DYSF\|FKRP\|LMNA\|MYOT\|SGCA\|SGCB\|SGCD\|SGCG | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515249.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515249 | FKTN\|POMGNT1\|POMT1\|POMT2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515254.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515254 | FKRP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515265.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515265 | FKRP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515270.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515270 | CAPN3\|CAV3\|DYSF\|FKRP\|LMNA\|MYOT\|SGCA\|SGCB\|SGCD\|SGCG | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000515349.1 | Athena Diagnostics Inc — Massachusetts 22D0069726 515349 | POMGNT1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | Yes
GTR000508280.2 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 508280 | AARS2\|AASS\|ABAT\|ABCA12\|ABCA4\|ABCB11\|ABCB4\|ABCB6\|ABCB7\|ABCD1\|ABHD12\|ABHD5\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACO2\|ACOX1\|ACSF3\|ACSL4\|ADAM9\|ADCK3\|ADSL\|AFG3L2\|AGK\|AGL\|AGPS\|AGXT\|AIFM1\|AIPL1\|AK1\|AK2\|AKAP10\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|ALDOA\|ALDOB\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ALMS1\|AMACR\|AMER1\|AMN\|AMT\|ANKH\|ANKRD26\|AP3B1\|APP\|APTX\|ARG1\|ARL6\|ASL\|ASS1\|ATIC\|ATP5E\|ATP6V0A2\|ATP7A\|ATP7B\|ATP8B1\|ATPAF2\|AUH\|B4GALT1\|B4GALT7\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BCKDHA\|BCKDHB\|BCOR\|BCS1L\|BEST1\|BLOC1S3\|BOLA3\|BRCA1\|BTD\|C10orf2\|C12orf65\|C1QTNF5\|C2orf71\|C8orf37\|CA2\|CA4\|CABP4\|CACNA1F\|CACNA2D4\|CASP8\|CAT\|CBS\|CC2D2A\|CCDC28B\|CCDC39\|CDH23\|CDHR1\|CEP290\|CERKL\|CHAT\|CHM\|CISD2\|CLCN7\|CLN3\|CLRN1\|CNGA1\|CNGA3\|CNGB1\|CNGB3\|COG1\|COG7\|COG8\|COL1A1\|COL1A2\|COL2A1\|COL3A1\|COL5A1\|COL5A2\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|CPOX\|CPS1\|CPT1A\|CPT2\|CRB1\|CRTAP\|CRX\|CRYAB\|CTSA\|CTSD\|CTSK\|CUBN\|CYB5A\|CYB5R3\|CYBA\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP17A1\|CYP1B1\|CYP24A1\|CYP27A1\|CYP27B1\|CYP4V2\|D2HGDH\|DARS2\|DBT\|DDOST\|DFNB31\|DGUOK\|DHDDS\|DHODH\|DIABLO\|DLAT\|DLD\|DMGDH\|DNAJC19\|DNM1L\|DPM1\|DPM3\|DSP\|DTNBP1\|EFEMP1\|ELAC2\|ELN\|ELOVL4\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|EYA1\|EYA4\|EYS\|FAH\|FAM161A\|FAM20C\|FASTKD2\|FBLN5\|FBN1\|FBP1\|FECH\|FH\|FKBP10\|FLVCR1\|FOXC1\|FOXL2\|FOXRED1\|FRMD7\|FSCN2\|FXN\|FYCO1\|FZD4\|G6PC\|GAA\|GAD1\|GALC\|GALE\|GALK1\|GALNS\|GALT\|GAMT\|GARS\|GATM\|GBE1\|GCDH\|GCK\|GCKR\|GCSH\|GFER\|GFM1\|GIF\|GJA3\|GK\|GLB1\|GLDC\|GLRX5\|GLUD1\|GLYCTK\|GM2A\|GNAT1\|GNAT2\|GNE\|GNPTAB\|GNS\|GOT1\|GPD1\|GPD2\|GPI\|GPR143\|GPR98\|GPX1\|GRK1\|GRM6\|GRN\|GSN\|GUCA1A\|GUCA1B\|GUCY2D\|GUSB\|GYS1\|GYS2\|HADHA\|HADHB\|HAGH\|HARS\|HAX1\|HBB\|HCCS\|HESX1\|HEXA\|HEXB\|HGSNAT\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HNF1A\|HNF1B\|HP\|HPRT1\|HPS1\|HPS3\|HPS4\|HPS5\|HPS6\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH2\|IDH3B\|IMPDH1\|IMPG2\|INPP5E\|INVS\|IQCB1\|ISCU\|IVD\|JAG1\|KARS\|KCNJ13\|KCNV2\|KIF1B\|KIF21A\|KLHL7\|KRT12\|KRT3\|KRT5\|L2HGDH\|LCA5\|LDHA\|LDHB\|LEMD3\|LEPRE1\|LIAS\|LMBRD1\|LMX1B\|LPIN1\|LRAT\|LRP5\|LRPPRC\|MAN2B1\|MANBA\|MAOA\|MC1R\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MEF2A\|MEN1\|MERTK\|MFN2\|MFRP\|MGAT2\|MKKS\|MKS1\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MPDU1\|MPI\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MSRB3\|MTHFR\|MTO1\|MTPAP\|MTR\|MTRR\|MUT\|MUTYH\|MYO7A\|MYOC\|NAGLU\|NAGS\|NCOA4\|NDP\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NEFH\|NEUROD1\|NFU1\|NHS\|NME1\|NPHP1\|NPHP3\|NPHP4\|NRL\|NT5C3A\|NUBPL\|NYX\|OAT\|OCA2\|OCRL\|OGDH\|OGG1\|OPA1\|OPA3\|OPN1LW\|OPN1MW\|OPTN\|OSTM1\|OTC\|OTX2\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PAX2\|PAX6\|PC\|PCCA\|PCCB\|PCDH15\|PCK2\|PDE6A\|PDE6B\|PDE6C\|PDE6G\|PDHA1\|PDHB\|PDP1\|PDSS1\|PDSS2\|PDZD7\|PFKM\|PGAM2\|PGM1\|PHB\|PHKA1\|PHKA2\|PHKB\|PHKG2\|PHOX2A\|PHYH\|PINK1\|PITPNM3\|PITX2\|PITX3\|PLA2G2A\|PLOD2\|PLOD3\|PMM2\|PNKD\|PNPLA2\|POLG\|POLG2\|PPARG\|PPARGC1B\|PPIB\|PPOX\|PPP2R1B\|PRCD\|PRKCG\|PRODH\|PROM1\|PRPF31\|PRPF6\|PRPF8\|PRPH2\|PSAP\|PSEN1\|PTRF\|PTS\|PUS1\|PYCR1\|PYGL\|PYGM\|QDPR\|RAF1\|RARS2\|RAX\|RB1\|RD3\|RDH12\|RDH5\|REEP1\|RET\|RFT1\|RGR\|RGS9\|RHO\|RILP\|RIMS1\|RLBP1\|RNASEL\|RP1\|RP1L1\|RP2\|RP9\|RPE65\|RPGR\|RPGRIP1\|RPL35A\|RPS14\|RRM2B\|RS1\|SAG\|SARDH\|SARS2\|SCO2\|SCP2\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SECISBP2\|SEMA4A\|SEPT9\|SERPINF1\|SGSH\|SHH\|SIX6\|SLC16A1\|SLC22A4\|SLC22A5\|SLC24A1\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC26A4\|SLC34A1\|SLC35A1\|SLC35C1\|SLC37A4\|SLC39A13\|SLC3A1\|SLC45A2\|SLC9A3R1\|SLC9A6\|SMPD1\|SNCB\|SNRNP200\|SOD1\|SOD2\|SOST\|SOX2\|SP7\|SPATA7\|SPG7\|SPR\|SPTLC2\|SQSTM1\|SRD5A3\|STAR\|STAT1\|STAT3\|STRA6\|STXBP1\|SUCLA2\|SUCLG1\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TCN2\|TEAD1\|TGFB1\|TGFBI\|TIMM8A\|TIMP3\|TK2\|TLR3\|TLR4\|TMEM126A\|TMEM127\|TMEM67\|TMEM70\|TNFRSF11A\|TNFRSF11B\|TNFSF11\|TOPORS\|TP53\|TPP1\|TRIM32\|TRMU\|TRPM1\|TSFM\|TSPAN12\|TTC19\|TTC8\|TUBA1A\|TUBB3\|TUFM\|TULP1\|TUSC3\|TYMP\|TYR\|TYROBP\|TYRP1\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|USH1C\|USH1G\|USH2A\|VCP\|VHL\|VSX1\|WFS1\|WT1\|WWOX\|XDH\|XPNPEP3\|YARS2\|ZEB1\|ZFHX3\|ZNF513 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | Not reported | Not reported
GTR000511381.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511381 | ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ATP6V0A2\|B4GALT1\|COG1\|COG7\|COG8\|DOLK\|DPAGT1\|DPM1\|DPM3\|GNE\|MGAT2\|MOGS\|MPDU1\|MPI\|PMM2\|RFT1\|SLC35A1\|SLC35C1\|SRD5A3\|TUSC3 | Deletion/duplication analysis | Microarray | Not reported | Decline to answer | No
GTR000511382.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511382 | ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ATP6V0A2\|B4GALT1\|COG1\|COG7\|COG8\|DOLK\|DPAGT1\|DPM1\|DPM3\|GNE\|MGAT2\|MOGS\|MPDU1\|MPI\|PMM2\|RFT1\|SLC35A1\|SLC35C1\|SRD5A3\|TUSC3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | Decline to answer | No
GTR000511387.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511387 | ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ATP6V0A2\|B4GALT1\|COG1\|COG7\|COG8\|DOLK\|DPAGT1\|DPM1\|DPM3\|GNE\|MGAT2\|MOGS\|MPDU1\|MPI\|PMM2\|RFT1\|SLC35A1\|SLC35C1\|SRD5A3\|TUSC3 | Sequence analysis of select exons | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | Decline to answer | No
GTR000511520.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511520 | HSD17B10 | Deletion/duplication analysis | Microarray | Not reported | Decline to answer | No
GTR000511521.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511521 | HSD17B10 | Sequence analysis of select exons | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000511522.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511522 | HSD17B10 | Sequence analysis of select exons | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000511523.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511523 | HSD17B10 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000511524.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511524 | HSD17B10 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000511814.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511814 | ARX | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis\|Multiplex Ligation-dependent Probe Amplification (MLPA) | Not reported | Not reported | No
GTR000511815.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511815 | ARX | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Not reported | Not reported | No
GTR000511816.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511816 | ARX | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Not reported | Not reported | No
GTR000511817.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511817 | ARX | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000511818.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511818 | ARX | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000511819.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511819 | ARX | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512051.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512051 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512052.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512052 | MECP2 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | Not reported | No
GTR000512053.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512053 | MECP2 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | Not reported | No
GTR000512054.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512054 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512055.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512055 | MECP2 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512056.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512056 | MECP2 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512057.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512057 | MEF2C | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512058.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512058 | MEF2C | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512059.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512059 | MEF2C | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000504097.1 | Center for Genetics at Saint Francis Saint Francis Hospital Oklahoma 37D0474681 504097 | FGFR1\|FGFR2\|FGFR3 | Sequence analysis of select exons\|Targeted variant analysis | Bi-directional Sanger Sequence Analysis\|SNP Detection | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | No
GTR000504103.1 | Center for Genetics at Saint Francis Saint Francis Hospital Oklahoma 37D0474681 504103 | FGFR2\|TWIST1 | Sequence analysis of select exons\|Targeted variant analysis | Bi-directional Sanger Sequence Analysis\|SNP Detection | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000291094.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291094 | FTSJ1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291100.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291100 | TSPAN7 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291120.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291120 | ACSL4 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291122.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291122 | ZNF41 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291134.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291134 | KDM5C | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291140.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291140 | DLG3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291157.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291157 | PAK3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291160.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291160 | ARHGEF6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291163.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291163 | AGTR2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291172.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291172 | ATP6AP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000291505.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 291505 | OPHN1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000319423.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 319423 | GDI1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000321516.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 321516 | SYNGAP1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000322960.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 322960 | RAB39B | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | No
GTR000505960.1 | Center for Human Genetics, Inc — Massachusetts 22D0650242 505960 | ARX | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000500883.8 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500883 | ABAT\|ABCC2\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|AKT3\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASAH1\|ASPA\|ASPM\|ATIC\|ATN1\|ATP1A2\|ATP1A3\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BRAF\|BRAT1\|BRD2\|BTD\|BUB1B\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT1A\|CPT2\|CSTB\|CTSA\|CTSD\|CTSF\|CUL4B\|CYP1B1\|CYP2A6\|CYP2B6\|CYP2C19\|CYP2C9\|CYP2D6\|CYP2R1\|CYP2U1\|CYP3A5\|DBT\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FAAH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FOXH1\|FUCA1\|GABBR2\|GABRA1\|GABRA2\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDH2\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIAS\|LIG4\|LRPPRC\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED12\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NGLY1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPA1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PIK3CA\|PIK3R2\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|RTTN\|SAMHD1\|SCARB2\|SCN10A\|SCN11A\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGCE\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SNIP1\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|ST3GAL5\|STIL\|STRADA\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TRPM6\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | No
GTR000500936.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500936 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|C21orf33\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|G6PD\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|HTT\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000503671.2 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 503671 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000510912.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 510912 | ADSL\|ALDH7A1\|ARHGEF9\|ARX\|ATP6AP2\|CACNB4\|CDKL5\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CSTB\|CTSD\|EFHC1\|EPM2A\|FOLR1\|FOXG1\|GABRA1\|GABRG2\|GAMT\|GATM\|GOSR2\|GRIN2A\|KANSL1\|KCNJ10\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|LGI1\|LIAS\|MAGI2\|MBD5\|MECP2\|MEF2C\|MFSD8\|NHLRC1\|NRXN1\|PCDH19\|PLCB1\|PNKP\|PNPO\|POLG\|PPT1\|PRICKLE1\|PRRT2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|STXBP1\|SYN1\|SYNGAP1\|TBC1D24\|TCF4\|TPP1\|TSC1\|TSC2\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fetal blood\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000514881.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514881 | AASS\|ABAT\|ABCD1\|ABCD3\|ABCD4\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADVL\|ACAT1\|ACOX1\|AGA\|ALDH3A2\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMN\|AMT\|APTX\|ARG1\|ARSA\|ASL\|ASS1\|ATP7A\|ATP7B\|AUH\|B4GALT1\|BCKDHA\|BCKDHB\|BTD\|CACNA1H\|CBS\|CHAT\|CISD2\|CLN3\|CLN5\|CLN6\|CLN8\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COQ2\|COQ9\|CP\|CPS1\|CPT1A\|CPT2\|CTSA\|CTSD\|CTSF\|CUBN\|CYP27A1\|DBH\|DBT\|DDC\|DDOST\|DHDDS\|DHFR\|DLAT\|DLD\|DNAJC5\|DOLK\|DPAGT1\|DPM1\|DPM2\|DPM3\|DPYD\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|ETFA\|ETFB\|ETFDH\|ETHE1\|FKRP\|FKTN\|FTCD\|FUCA1\|GAA\|GALC\|GAMT\|GATM\|GBA\|GCDH\|GCH1\|GCSH\|GIF\|GK\|GLB1\|GLDC\|GLUD1\|GNE\|GNPAT\|GNPTAB\|GRN\|GUSB\|HADH\|HADHA\|HADHB\|HEXA\|HEXB\|HLCS\|HMGCL\|HMGCS2\|HSD17B10\|HYAL1\|IDS\|IDUA\|IVD\|KCTD7\|L2HGDH\|LARS2\|LIPA\|LMBRD1\|MAGT1\|MAN2B1\|MANBA\|MCCC1\|MCCC2\|MCEE\|MFSD8\|MGAT2\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|MUT\|NAGA\|NAGS\|NDUFA1\|NEU1\|NPC1\|NPC2\|OTC\|OXCT1\|PAH\|PCBD1\|PCCA\|PCCB\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PHGDH\|PHYH\|PMM2\|PNPO\|POMGNT1\|POMT1\|POMT2\|PPT1\|PRPS1\|PSAT1\|PSPH\|PTS\|QDPR\|RFT1\|SLC16A2\|SLC17A5\|SLC19A2\|SLC19A3\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A20\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC6A3\|SLC6A4\|SMPD1\|SPR\|SRD5A3\|ST3GAL3\|STT3A\|STT3B\|SUMF1\|SUOX\|TAT\|TH\|TIMM8A\|TMEM165\|TMLHE\|TPH2\|TPP1\|TUBA1A | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva | Decline to answer | No
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000501305.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501305 | UPF3B | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501308.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501308 | UPF3B | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501310.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501310 | IL1RAPL1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501311.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501311 | IL1RAPL1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501313.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501313 | PAK3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501314.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501314 | PAK3 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501315.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501315 | ACSL4 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501316.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501316 | ACSL4 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501334.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501334 | GDI1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501335.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501335 | ZNF81 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501336.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501336 | GDI1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501337.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501337 | ZNF81 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501339.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501339 | POMT1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501340.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501340 | POMT2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501341.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501341 | POMT2 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501342.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501342 | POMT1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501344.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501344 | ARHGEF6 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501345.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501345 | ARX | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501346.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501346 | TSPAN7 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501348.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501348 | ARX | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501349.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501349 | ARHGEF6 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501350.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501350 | TSPAN7 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501351.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501351 | AP1S2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501352.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501352 | MBD5 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501353.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501353 | RAB39B | Mutation scanning of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501354.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501354 | MBD5 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501355.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501355 | AP1S2 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501356.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501356 | RAB39B | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501445.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501445 | AGTR2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501446.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501446 | ZNF41 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501447.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501447 | AGTR2 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501448.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501448 | ZNF41 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501449.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501449 | ZDHHC15 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501451.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501451 | ZNF674 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501456.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501456 | ZDHHC15 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501459.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501459 | ZNF674 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501463.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501463 | BRWD3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501468.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501468 | GRIA3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501470.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501470 | BRWD3 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501471.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501471 | GRIA3 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501507.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501507 | CASK | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501508.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501508 | CASK | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501516.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501516 | DLG3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501518.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501518 | DLG3 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501602.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501602 | MAGT1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501605.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501605 | MAGT1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501608.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501608 | IGBP1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501610.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501610 | OPHN1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501612.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501612 | IGBP1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501613.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501613 | OPHN1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501636.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501636 | SOX3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501637.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501637 | SRPX2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501638.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501638 | SOX3 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501639.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501639 | SRPX2 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501640.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501640 | ZDHHC9 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501641.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501641 | ZNF711 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501642.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501642 | ZDHHC9 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501643.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501643 | ZNF711 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501653.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501653 | FTSJ1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501655.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501655 | FTSJ1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501659.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501659 | HSD17B10 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501660.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501660 | HSD17B10 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501662.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501662 | KDM5C | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501664.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501664 | KDM5C | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501665.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501665 | KIAA2022 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501667.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501667 | KIAA2022 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501708.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501708 | ATP6AP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501711.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501711 | ATP6AP2 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501732.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501732 | MED12 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501733.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501733 | MED12 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501734.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501734 | FOXP1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501736.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501736 | FOXP1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000501738.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501738 | MEF2C | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000501741.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501741 | MEF2C | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502397.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502397 | FKRP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502398.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502398 | LARGE | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502450.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502450 | FKRP | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502451.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502451 | LARGE | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502786.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502786 | TUSC3 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502789.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502789 | TUSC3 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502828.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502828 | PHF8 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502830.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502830 | PHF8 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502834.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502834 | SYP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502835.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502835 | SYP | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502836.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502836 | UBE2A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502837.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502837 | UBE2A | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502838.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502838 | HUWE1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502839.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502839 | HUWE1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502845.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502845 | CUL4B | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000502846.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502846 | CUL4B | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000503216.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503216 | COL6A1\|COL6A2\|COL6A3\|FKRP\|FKTN\|ITGA7\|LAMA2\|LARGE\|POMGNT1\|POMT1\|POMT2\|SEPN1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000503227.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503227 | COL6A1\|COL6A2\|COL6A3\|FKRP\|FKTN\|ITGA7\|LAMA2\|LARGE\|POMGNT1\|POMT1\|POMT2\|SEPN1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000512325.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512325 | ABCC9\|ACTA2\|ACTC1\|ACTN2\|ACVRL1\|AKAP9\|ANK2\|ANKRD1\|BAG3\|BMPR2\|BRAF\|CACNA1C\|CACNB2\|CASQ2\|CAV1\|CAV3\|CBS\|COL3A1\|COL5A1\|COL5A2\|CRYAB\|CSRP3\|DES\|DMD\|DSC2\|DSG2\|DSP\|DTNA\|EMD\|ENG\|FBN1\|FBN2\|FHL2\|FKTN\|FLNA\|GATAD1\|GLA\|GPD1L\|HCN4\|HRAS\|JPH2\|JUP\|KCNE1\|KCNE2\|KCNE3\|KCNH2\|KCNJ2\|KCNJ5\|KCNJ8\|KCNQ1\|KRAS\|LAMA4\|LAMP2\|LDB3\|LMNA\|MAP2K1\|MAP2K2\|MED12\|MYBPC3\|MYH11\|MYH6\|MYH7\|MYL2\|MYL3\|MYLK2\|MYOZ2\|MYPN\|NEBL\|NEXN\|NKX2-5\|NR2F2\|NRAS\|PKP2\|PLN\|PRKAG2\|PTPN11\|RAF1\|RANGRF\|RBM20\|RYR2\|SCN1B\|SCN3B\|SCN4B\|SCN5A\|SGCD\|SKI\|SLC2A10\|SMAD3\|SNTA1\|SOS1\|TAZ\|TCAP\|TGFB2\|TGFBR1\|TGFBR2\|TMEM43\|TMPO\|TNNC1\|TNNI3\|TNNT2\|TPM1\|TTN\|TTR\|VCL | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | No | No
GTR000512331.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512331 | ACTA2\|CBS\|COL3A1\|COL5A1\|COL5A2\|FBN1\|FBN2\|FLNA\|MED12\|MYH11\|SKI\|SLC2A10\|SMAD3\|TGFB2\|TGFBR1\|TGFBR2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | No | No
GTR000512362.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512362 | ABCA4\|ADAM9\|AIPL1\|BEST1\|C8orf37\|CABP4\|CACNA1F\|CACNA2D4\|CDHR1\|CEP290\|CERKL\|CNGA3\|CNGB3\|CNNM4\|CRX\|GNAT2\|GUCA1A\|GUCA1B\|GUCY2D\|KCNV2\|PAX6\|PDE6C\|PDE6H\|PITPNM3\|PROM1\|PRPH2\|RAX2\|RBP4\|RDH5\|RGS9\|RGS9BP\|RIMS1\|RPGR\|RPGRIP1\|SEMA4A\|UNC119 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512371.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512371 | B3GALTL\|BCOR\|BMP4\|COL4A1\|CYP1B1\|FOXC1\|FOXE3\|FRAS1\|FREM1\|FREM2\|GRIP1\|HCCS\|MFRP\|NDP\|OTX2\|PAX6\|PITX2\|PITX3\|SMOC1\|SOX2\|STRA6\|VAX1\|VSX2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512373.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512373 | ABCA4\|ABHD12\|ADAM9\|AHI1\|AIPL1\|ALMS1\|ARL13B\|ARL6\|B3GALTL\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BCOR\|BEST1\|BMP4\|C1QTNF5\|C2orf71\|C5orf42\|C8orf37\|CA4\|CABP4\|CACNA1F\|CACNA2D4\|CC2D2A\|CDH23\|CDH3\|CDHR1\|CEP290\|CEP41\|CERKL\|CHM\|CIB2\|CLN3\|CLN5\|CLN6\|CLN8\|CLRN1\|CNGA1\|CNGA3\|CNGB1\|CNGB3\|CNNM4\|COL11A1\|COL11A2\|COL2A1\|COL4A1\|COL9A1\|COL9A2\|CRB1\|CRX\|CTSD\|CYP1B1\|DFNB31\|DHDDS\|EFEMP1\|ELOVL4\|EYS\|FAM161A\|FLVCR1\|FOXC1\|FOXE3\|FRAS1\|FREM1\|FREM2\|FSCN2\|FZD4\|GNAT1\|GNAT2\|GPR143\|GPR179\|GPR98\|GRIP1\|GRM6\|GRN\|GUCA1A\|GUCA1B\|GUCY2D\|HARS\|HCCS\|IDH3B\|IMPDH1\|IMPG2\|INVS\|IQCB1\|KCNJ13\|KCNV2\|KCTD7\|KIF7\|KLHL7\|LCA5\|LRAT\|LRIT3\|LRP5\|LZTFL1\|MAK\|MERTK\|MFN2\|MFRP\|MFSD8\|MKKS\|MKS1\|MYO7A\|MYOC\|NDP\|NPHP1\|NPHP3\|NPHP4\|NR2E3\|NRL\|NYX\|OCA2\|OFD1\|OPA1\|OPA3\|OTX2\|PAX6\|PCDH15\|PDE6A\|PDE6B\|PDE6C\|PDE6G\|PDE6H\|PDZD7\|PEX7\|PHYH\|PITPNM3\|PITX2\|PITX3\|PLA2G5\|PPT1\|PRCD\|PROM1\|PRPF3\|PRPF31\|PRPF6\|PRPF8\|PRPH2\|RAX2\|RBP3\|RBP4\|RD3\|RDH12\|RDH5\|RGR\|RGS9\|RGS9BP\|RHO\|RIMS1\|RLBP1\|ROM1\|RP1\|RP2\|RP9\|RPE65\|RPGR\|RPGRIP1\|RPGRIP1L\|RS1\|SAG\|SDCCAG8\|SEMA4A\|SLC24A1\|SLC45A2\|SMOC1\|SNRNP200\|SOX2\|SPATA7\|STRA6\|TCTN1\|TCTN2\|TCTN3\|TIMM8A\|TIMP3\|TMEM126A\|TMEM216\|TMEM237\|TMEM67\|TOPORS\|TPP1\|TRIM32\|TRPM1\|TSPAN12\|TTC21B\|TTC8\|TULP1\|TYR\|TYRP1\|UNC119\|USH1C\|USH1G\|USH2A\|VAX1\|VCAN\|VSX2\|WDPCP\|WT1\|ZNF423\|ZNF513 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512377.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512377 | ABCA4\|BEST1\|CDH3\|CNGB3\|EFEMP1\|ELOVL4\|FSCN2\|GUCA1B\|PROM1\|PRPH2\|RBP4\|RDH12\|RPGR\|RPGRIP1\|TIMP3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512415.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512415 | ACVR2B\|AHI1\|AIPL1\|ARL13B\|ARL6\|ATXN10\|B9D1\|B9D2\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|C2orf71\|C5orf42\|CC2D2A\|CCDC28B\|CCDC39\|CCDC40\|CDH23\|CEP164\|CEP290\|CEP41\|CFTR\|CLRN1\|CRB1\|CRELD1\|CRX\|DFNB31\|DNAAF1\|DNAAF2\|DNAAF3\|DNAH11\|DNAH5\|DNAI1\|DNAI2\|DNAL1\|DYNC2H1\|EVC\|EVC2\|FOXH1\|GDF1\|GLIS2\|GPR98\|GUCY2D\|HYLS1\|IFT43\|IFT80\|IMPDH1\|INVS\|IQCB1\|KCNJ13\|KIF7\|LCA5\|LEFTY2\|LRAT\|MKKS\|MKS1\|MYO7A\|NEK1\|NEK8\|NKX2-5\|NME8\|NODAL\|NPHP1\|NPHP3\|NPHP4\|OFD1\|PCDH15\|PKD2\|PKHD1\|RD3\|RDH12\|RPE65\|RPGR\|RPGRIP1\|RPGRIP1L\|RSPH4A\|RSPH9\|SCNN1A\|SCNN1B\|SCNN1G\|SDCCAG8\|SPATA7\|TCTN1\|TCTN2\|TMEM138\|TMEM216\|TMEM231\|TMEM237\|TMEM67\|TOPORS\|TRIM32\|TSC1\|TSC2\|TTC21B\|TTC8\|TULP1\|UMOD\|USH1C\|USH1G\|USH2A\|VHL\|WDPCP\|WDR19\|WDR35\|XPNPEP3\|ZIC3\|ZNF423 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512416.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512416 | ABAT\|ADSL\|ALDH7A1\|ARHGEF9\|ARX\|ASPM\|ATP1A2\|ATP6AP2\|BCKDK\|CACNA1A\|CACNB4\|CASK\|CASR\|CDKL5\|CENPJ\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CPA6\|CSTB\|CTSD\|DCX\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FLNA\|FOLR1\|FOXG1\|GABRA1\|GABRG2\|GAMT\|GATM\|GOSR2\|GPR56\|GPR98\|GRIN2A\|HCN1\|HCN4\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|LGI1\|LIAS\|MAGI2\|MBD5\|MCPH1\|MECP2\|MEF2C\|MFSD8\|MTHFR\|NDE1\|NDUFA1\|NHLRC1\|NRXN1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PLCB1\|PNKP\|PNPO\|POLG\|PPT1\|PRICKLE1\|PRICKLE2\|PRRT2\|RELN\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN3A\|SCN8A\|SCN9A\|SHH\|SIX3\|SLC19A3\|SLC25A19\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|SRPX2\|ST3GAL3\|ST3GAL5\|STIL\|STXBP1\|SYN1\|TBC1D24\|TCF4\|TPP1\|TSC1\|TSC2\|TSEN54\|UBE3A\|WDR62\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512417.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512417 | ADAM17\|AICDA\|ATG16L1\|BTK\|C1orf106\|CD40LG\|COL7A1\|CYBA\|CYBB\|DCLRE1C\|DOCK8\|ERAP2\|FERMT1\|FOXP3\|FUT2\|G6PC3\|GUCY2C\|HPS1\|HPS4\|HPS6\|ICOS\|IL10\|IL10RA\|IL18RAP\|IL23R\|IL2RA\|IRGM\|ITGAM\|LRBA\|MEFV\|MVK\|NCF2\|NCF4\|NOD2\|PIK3R1\|PLCG2\|PTEN\|PTPN22\|RAC2\|RB1\|RET\|SH2D1A\|SLC37A4\|STAT1\|STXBP2\|TTC37\|WAS\|XIAP | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512422.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512422 | ACTA1\|AMPD1\|AMPD3\|ANO5\|CAPN3\|CAV3\|COL6A1\|COL6A2\|COL6A3\|DES\|DMD\|DYSF\|EMD\|FKRP\|FKTN\|GAA\|GNE\|ISPD\|ITGA7\|LAMA2\|LARGE\|LMNA\|MYOT\|NEB\|PLEC\|PMM2\|POMGNT1\|POMT1\|POMT2\|PYGM\|RYR1\|RYR2\|SEPN1\|SGCA\|SGCB\|SGCD\|SGCE\|SGCG\|SIL1\|TCAP\|TNNI2\|TNNT1\|TPM2\|TPM3\|TRIM32\|TTN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512423.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512423 | ATRX\|BLM\|BTK\|CREBBP\|CUL7\|DHCR7\|EP300\|ERCC6\|ERCC8\|FGD1\|GH1\|GHR\|GHRHR\|GLI2\|HESX1\|IGF1\|IGF1R\|INSR\|KDM6A\|KMT2D\|KRAS\|LHX3\|NBN\|NIPBL\|PITX2\|POU1F1\|PROP1\|PTPN11\|RAF1\|ROR2\|RPS6KA3\|SHOX\|SHOX2\|SMARCAL1\|SMC1A\|SMC3\|SOS1\|SOX2\|SOX3\|SRCAP\|STAT5B\|TBCE\|THRB\|TRIM37\|WRN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512586.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512586 | ABCD1\|ACSL4\|AFF2\|AP1S2\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDK16\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|HCCS\|HCFC1\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|KLF8\|L1CAM\|LAMP2\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SYN1\|SYP\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|ZDHHC15\|ZDHHC9\|ZNF711 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512587.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512587 | ADSL\|AFF2\|AP1S2\|ARX\|ATRX\|BCKDK\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DHCR7\|DMD\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|HPRT1\|KDM5C\|L1CAM\|MAGEL2\|MBD5\|MECP2\|MED12\|MEF2C\|MID1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NR1I3\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RELN\|SCN1A\|SLC2A1\|SLC9A6\|SMARCB1\|SMC1A\|TCF4\|UBE2A\|UBE3A\|VPS13B\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512588.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512588 | ACTB\|ACTG1\|AHI1\|ARFGEF2\|ARX\|CASK\|CC2D2A\|CEP290\|CEP41\|CHMP1A\|DCX\|EOMES\|EXOSC3\|FKRP\|FKTN\|FLNA\|GPR56\|KIAA1279\|KIF7\|LAMC3\|LARGE\|MKS1\|NPHP1\|OPHN1\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|PQBP1\|RAB3GAP1\|RAB3GAP2\|RARS2\|RELN\|RPGRIP1L\|RTTN\|SRPX2\|TMEM138\|TMEM216\|TMEM237\|TMEM67\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|VLDLR\|VRK1\|WDR62 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512591.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512591 | ALG1\|ALG11\|ALG12\|ALG13\|ALG14\|ALG3\|ALG6\|ALG8\|ALG9\|ATP6V0A2\|B3GALTL\|B3GAT3\|B4GALT1\|B4GALT7\|CHST14\|CHST3\|CHST6\|CHSY1\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|DDOST\|DHDDS\|DOLK\|DPAGT1\|DPM1\|DPM3\|EXT1\|EXT2\|FKRP\|FKTN\|GALNT3\|GFPT1\|GNE\|LARGE\|LFNG\|MAN1B1\|MGAT2\|MOGS\|MPDU1\|MPI\|NGLY1\|PGM1\|PIGA\|PIGL\|PIGM\|PIGO\|PIGV\|PMM2\|POMGNT1\|POMT1\|POMT2\|RFT1\|RPN2\|SEC23B\|SLC35A1\|SLC35C1\|SLC35D1\|SRD5A3\|ST3GAL3\|ST3GAL5\|TMEM165\|TUSC3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512592.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512592 | CHKB\|COL6A1\|COL6A2\|COL6A3\|DAG1\|DPM2\|DPM3\|FKRP\|FKTN\|ISPD\|ITGA7\|LAMA2\|LARGE\|LMNA\|POMGNT2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512595.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512595 | ACP5\|ANKH\|ANO5\|B3GALT6\|BMPR1B\|CANT1\|CDKN1C\|CHST14\|CHST3\|COL10A1\|COL11A1\|COL11A2\|COL1A1\|COL2A1\|COL9A1\|COL9A2\|COL9A3\|COMP\|CTSK\|CUL7\|DDR2\|DHCR24\|DYM\|DYNC2H1\|EIF2AK3\|EVC\|EVC2\|EXT1\|EXT2\|FAM20C\|FBN1\|FGFR1\|FGFR2\|FGFR3\|FLNA\|FLNB\|GDF5\|GLI3\|GPC6\|HSPG2\|ICK\|IFT122\|IFT140\|IFT80\|IHH\|KIF22\|LIFR\|MATN3\|MMP13\|MMP9\|NEK1\|NKX3-2\|NPR2\|OBSL1\|PAPSS2\|PCNT\|PRKAR1A\|PTH1R\|PTPN11\|ROR2\|RUNX2\|SH3PXD2B\|SHOX\|SLC25A12\|SLC26A2\|SLC35D1\|SLC39A13\|SMARCAL1\|SOX9\|SULF1\|TBCE\|TCTN3\|TRIP11\|TRPS1\|TRPV4\|WDR35\|WNT5A | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512597.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512597 | ACTA1\|AMPD1\|AMPD3\|ANO5\|BAG3\|BIN1\|BSCL2\|CAPN3\|CAV3\|CFL2\|CHAT\|CHRNA1\|CHRNB1\|CHRND\|CHRNE\|CHRNG\|COL6A1\|COL6A2\|COL6A3\|COLQ\|CRYAB\|DAG1\|DES\|DMD\|DNM2\|DOK7\|DYSF\|EMD\|FHL1\|FKRP\|FKTN\|FLNC\|GAA\|GLE1\|GNE\|IGHMBP2\|ISPD\|ITGA7\|LAMA2\|LARGE\|LDB3\|LMNA\|MTM1\|MTMR14\|MUSK\|MYH2\|MYH7\|MYOT\|NEB\|PABPN1\|PLEC\|PLEKHG5\|PMM2\|POMGNT1\|POMT1\|POMT2\|PTRF\|PYGM\|RAPSN\|RYR1\|RYR2\|SCN4A\|SEPN1\|SGCA\|SGCB\|SGCD\|SGCE\|SGCG\|SIL1\|SYNE1\|SYNE2\|TCAP\|TNNI2\|TNNT1\|TPM2\|TPM3\|TRIM32\|TTN\|VRK1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512601.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512601 | ABHD12\|ABHD5\|ACTG1\|ARSB\|ATP6V1B1\|BSND\|BTD\|CCDC50\|CDH23\|CEACAM16\|CISD2\|CLDN14\|CLRN1\|COCH\|COL11A2\|COL4A5\|CRYM\|DFNA5\|DFNB31\|DFNB59\|DIAPH1\|DNMT1\|DSPP\|ESRRB\|EYA1\|EYA4\|FGFR3\|FOXC1\|FOXI1\|GIPC3\|GJB2\|GJB3\|GJB6\|GPR98\|GPSM2\|GRHL2\|GRXCR1\|HARS2\|HGF\|HSD17B4\|ILDR1\|KCNE1\|KCNJ10\|KCNQ1\|KCNQ4\|LHFPL5\|LOXHD1\|LRTOMT\|MARVELD2\|MASP1\|MSRB3\|MYH14\|MYH9\|MYO15A\|MYO1A\|MYO3A\|MYO6\|MYO7A\|OTOA\|OTOF\|PCDH15\|PDZD7\|PITX2\|POU3F4\|PRPS1\|RPS6KA3\|SALL1\|SALL4\|SERPINB6\|SIX1\|SLC17A8\|SLC26A4\|SLC26A5\|SLC29A3\|SMPX\|TECTA\|TIMM8A\|TJP2\|TMC1\|TMIE\|TMPRSS3\|TPRN\|TRIOBP\|USH1C\|USH1G\|USH2A\|WFS1 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512602.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512602 | DOCK8\|SPINK5\|STAT3\|TYK2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512604.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512604 | ARHGAP31\|BMP2\|BMPR1B\|CC2D2A\|CDH3\|CEP290\|CHSY1\|ESCO2\|FBLN1\|FBXW4\|FGF10\|FGFR2\|FGFR3\|FMN1\|GDF5\|GLI3\|GNAS\|GREM1\|HDAC4\|HOXD13\|IHH\|KIF7\|LMBR1\|LRP4\|MGP\|MKS1\|MYCN\|NIPBL\|NOG\|PIGV\|PITX1\|PTHLH\|RECQL4\|ROR2\|RPGRIP1L\|SALL1\|SALL4\|SHH\|SOX9\|TBX15\|TBX3\|TBX5\|THPO\|TP63\|WNT3\|WNT7A | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512605.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512605 | ANO5\|CAPN3\|CAV3\|DAG1\|DES\|DYSF\|FKRP\|FKTN\|FLNC\|LMNA\|MYOT\|PLEC\|POMGNT1\|POMT1\|POMT2\|SGCA\|SGCB\|SGCD\|SGCG\|TCAP\|TRIM32\|TTN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512606.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512606 | CUL4B\|EZH2\|GLI3\|GPC3\|MED12\|NFIX\|NSD1\|PHF6\|PTCH1\|PTEN\|UPF3B | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512608.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512608 | ACTB\|ACTG1\|ADSL\|AHI1\|ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ASPM\|ATP1A2\|ATP6AP2\|ATR\|ATRX\|BCKDK\|CACNB4\|CASC5\|CASK\|CC2D2A\|CDC6\|CDK5RAP2\|CDKL5\|CDT1\|CENPJ\|CEP135\|CEP152\|CEP290\|CEP41\|CEP63\|CHMP1A\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CPA6\|CSTB\|CTSD\|DCX\|DHCR7\|DISP1\|DNAJC5\|EFHC1\|EHMT1\|EOMES\|EPM2A\|EXOSC3\|FGF8\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FOXH1\|GABRA1\|GABRG2\|GAMT\|GATM\|GLI2\|GOSR2\|GPR56\|GPR98\|GRIN2A\|GRIN2B\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KIAA1279\|KIF7\|LAMC3\|LARGE\|LARP7\|LGI1\|LIAS\|MAGI2\|MAPK10\|MBD5\|MCPH1\|MECP2\|MEF2C\|MFSD8\|MKS1\|MYCN\|NDE1\|NHLRC1\|NIN\|NODAL\|NPHP1\|NRXN1\|OPHN1\|ORC4\|ORC6\|PAFAH1B1\|PCDH19\|PCNT\|PLCB1\|PNKP\|PNPO\|POC1A\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRRT2\|PTCH1\|RAB18\|RAB3GAP1\|RAB3GAP2\|RARS2\|RBBP8\|RELN\|RPGRIP1L\|RTTN\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SHH\|SIX3\|SLC19A3\|SLC25A19\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|SRPX2\|ST3GAL3\|ST3GAL5\|STIL\|STXBP1\|SYN1\|TBC1D24\|TCF4\|TGIF1\|TMEM138\|TMEM216\|TMEM237\|TMEM67\|TPP1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|UBE3A\|VLDLR\|VRK1\|WDR62\|ZEB2\|ZIC2\|ZNF335 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512610.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512610 | ABCA3\|ACVRL1\|AP3B1\|ASCL1\|BDNF\|BLOC1S3\|BLOC1S6\|BMPR2\|CCDC39\|CCDC40\|CFTR\|CSF2RA\|DNAAF1\|DNAAF2\|DNAH11\|DNAH5\|DNAI1\|DNAI2\|DNAL1\|DOCK8\|DTNBP1\|EDN3\|EFEMP2\|ELMOD2\|ELN\|ENG\|FBLN5\|FLCN\|GDNF\|HPS1\|HPS3\|HPS4\|HPS5\|HPS6\|LTBP4\|MUC5B\|NME8\|PHOX2B\|RET\|RSPH4A\|RSPH9\|SCNN1A\|SCNN1B\|SCNN1G\|SERPINA1\|SFTPA1\|SFTPA2\|SFTPB\|SFTPC\|SFTPD\|SMAD9\|STAT3\|TERT\|TSC1\|TSC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512649.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512649 | ACP5\|ALPL\|ANKH\|ANO5\|ARHGAP31\|ATP6V0A2\|B3GALT6\|B4GALT7\|BMP2\|BMPR1B\|CA2\|CANT1\|CASR\|CC2D2A\|CDH3\|CDKN1C\|CEP290\|CHST14\|CHST3\|CHSY1\|CLCN5\|CLCN7\|COL10A1\|COL11A1\|COL11A2\|COL1A1\|COL1A2\|COL2A1\|COL9A1\|COL9A2\|COL9A3\|COMP\|CRTAP\|CTSK\|CUL7\|DDR2\|DHCR24\|DLX3\|DMP1\|DYM\|DYNC2H1\|EIF2AK3\|ENPP1\|ESCO2\|EVC\|EVC2\|EXT1\|EXT2\|FAM20C\|FBLN1\|FBN1\|FBXW4\|FERMT3\|FGF10\|FGF23\|FGFR1\|FGFR2\|FGFR3\|FKBP10\|FLNA\|FLNB\|FMN1\|GALNT3\|GDF5\|GLI3\|GNAS\|GORAB\|GPC6\|GREM1\|HDAC4\|HOXD13\|HPGD\|HSPG2\|ICK\|IFITM5\|IFT122\|IFT140\|IFT80\|IHH\|KIF22\|KIF7\|LEMD3\|LEPRE1\|LIFR\|LMBR1\|LMNA\|LRP4\|LRP5\|MAFB\|MATN3\|MGP\|MKS1\|MMP13\|MMP2\|MMP9\|MYCN\|NEK1\|NIPBL\|NKX3-2\|NOG\|NOTCH2\|NPR2\|OBSL1\|OSTM1\|PAPSS2\|PCNT\|PHEX\|PIGV\|PITX1\|PLOD2\|PPIB\|PRKAR1A\|PTH1R\|PTHLH\|PTPN11\|PYCR1\|RASGRP2\|RECQL4\|ROR2\|RPGRIP1L\|RUNX2\|SALL1\|SALL4\|SERPINH1\|SH3PXD2B\|SHH\|SHOX\|SLC25A12\|SLC26A2\|SLC34A3\|SLC35D1\|SLC39A13\|SMARCAL1\|SOST\|SOX9\|SP7\|SULF1\|TBCE\|TBX15\|TBX3\|TBX5\|TBXAS1\|TCIRG1\|TCTN3\|TGFB1\|THPO\|TMEM216\|TMEM67\|TNFRSF11A\|TNFRSF11B\|TNFSF11\|TP63\|TREM2\|TRIP11\|TRPS1\|TRPV4\|TYROBP\|WDR35\|WISP3\|WNT3\|WNT5A\|WNT7A\|ZMPSTE24 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000505642.10 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 505642 | ACTA2\|CBS\|COL3A1\|COL5A1\|COL5A2\|FBN1\|FBN2\|FLNA\|MED12\|MYH11\|MYLK\|SKI\|SLC2A10\|SMAD3\|TGFB2\|TGFBR1\|TGFBR2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000505662.12 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 505662 | ANO5\|CAPN3\|CAV3\|DAG1\|DES\|DMD\|DNAJB6\|DPM3\|DYSF\|EMD\|FHL1\|FKRP\|FKTN\|LMNA\|MYOT\|POMGNT1\|POMT1\|POMT2\|PTRF\|SGCA\|SGCB\|SGCD\|SGCG\|SYNE1\|SYNE2\|TCAP\|TMEM43\|TRIM32\|TTN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000506412.12 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 506412 | ABCA4\|ADAM9\|AHI1\|AIPL1\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BCOR\|BEST1\|C2orf71\|CA4\|CABP4\|CACNA1F\|CACNA2D4\|CC2D2A\|CDH23\|CDH3\|CEP290\|CERKL\|CHM\|CLN3\|CNGA1\|CNGB1\|CNGB3\|CNNM4\|COL11A1\|COL2A1\|COL9A1\|CRB1\|CRX\|CYP1B1\|CYP4V2\|DFNB31\|EFEMP1\|ELOVL4\|EYS\|FAM161A\|FOXC1\|FSCN2\|GNAT1\|GRM6\|GUCA1A\|GUCA1B\|GUCY2D\|HMCN1\|IDH3B\|IMPDH1\|IMPG2\|INVS\|IQCB1\|JAG1\|KCNJ13\|KCNV2\|KLHL7\|LCA5\|LRAT\|MERTK\|MFRP\|MKKS\|MTTP\|MYOC\|NDP\|NPHP1\|NPHP3\|NPHP4\|NR2E3\|NRL\|OAT\|OPA1\|OPA3\|OPTN\|OTX2\|PANK2\|PAX2\|PAX6\|PCDH15\|PDE6A\|PDE6B\|PDE6C\|PDE6G\|PEX1\|PEX2\|PEX7\|PHYH\|PITPNM3\|PITX2\|PRCD\|PROM1\|PRPF3\|PRPF31\|PRPF8\|PRPH2\|RAX2\|RB1\|RBP3\|RBP4\|RD3\|RDH12\|RGR\|RGS9\|RGS9BP\|RHO\|RIMS1\|RLBP1\|ROM1\|RP1\|RP1L1\|RP2\|RP9\|RPE65\|RPGR\|RPGRIP1\|RPGRIP1L\|SAG\|SEMA4A\|SNRNP200\|SOX2\|SPATA7\|TIMM8A\|TIMP3\|TMEM126A\|TOPORS\|TREX1\|TRIM32\|TRPM1\|TTPA\|TULP1\|UNC119\|USH1C\|VCAN\|VSX2\|WFS1\|ZNF513 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000506437.10 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 506437 | ABCC9\|ACTC1\|ACTN2\|AKAP9\|ANK2\|ANKRD1\|BAG3\|CACNA1C\|CACNA2D1\|CACNB2\|CALR3\|CASQ2\|CAV3\|COX15\|CRYAB\|CSRP3\|DES\|DMD\|DOLK\|DSC2\|DSG2\|DSP\|DTNA\|EMD\|EYA4\|FKTN\|FLNA\|FXN\|GAA\|GATA4\|GATAD1\|GJA5\|GLA\|GPD1L\|HCN4\|ILK\|JAG1\|JPH2\|JUP\|KCNA5\|KCNE1\|KCNE2\|KCNE3\|KCNH2\|KCNJ2\|KCNJ5\|KCNJ8\|KCNQ1\|LAMA4\|LAMP2\|LDB3\|LMNA\|MRPL3\|MURC\|MYBPC3\|MYH6\|MYH7\|MYL2\|MYL3\|MYLK2\|MYOM1\|MYOZ2\|MYPN\|NDUFAF1\|NEBL\|NEXN\|NKX2-5\|NPPA\|PDLIM3\|PKP2\|PLN\|PRKAG2\|PSEN2\|PTPN11\|RAF1\|RBM20\|RYR2\|SCN1B\|SCN3B\|SCN4B\|SCN5A\|SDHA\|SGCD\|SNTA1\|SYNE1\|TAZ\|TBX1\|TBX5\|TCAP\|TGFB3\|TMEM43\|TMPO\|TNNC1\|TNNI3\|TNNT2\|TPM1\|TTN\|TTR\|TXNRD2\|VCL | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000507860.10 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 507860 | AARS\|ATL1\|DNM2\|DNMT1\|DYNC1H1\|EGR2\|FGD4\|GARS\|GDAP1\|GJB1\|GLA\|HSPB1\|HSPB8\|KIF1B\|LITAF\|LMNA\|LRSAM1\|MED25\|MFN2\|MPZ\|MTMR2\|NDRG1\|NEFL\|PMP22\|PRX\|RAB7A\|SBF2\|SCN9A\|SH3TC2\|SPTLC2\|TRPV4\|TTR\|YARS | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000508339.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 508339 | APC\|ATM\|ATR\|AXIN2\|BAP1\|BARD1\|BLM\|BMPR1A\|BRCA1\|BRCA2\|BRIP1\|CDH1\|CDK4\|CDKN2A\|CHEK2\|CTNNB1\|EPCAM\|FANCC\|HOXB13\|MLH1\|MRE11A\|MSH2\|MSH6\|MUTYH\|NBN\|PALB2\|PALLD\|PMS2\|PTEN\|RAD50\|RAD51\|RAD51C\|RAD51D\|SMAD4\|STK11\|TP53\|VHL\|XRCC2\|XRCC3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000508744.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 508744 | CASK\|OPHN1\|RARS2\|SEPSECS\|TSEN2\|TSEN34\|TSEN54\|VRK1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509342.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509342 | ANKRD11\|AP1S2\|ARX\|ATRX\|AUTS2\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CHD8\|CNTNAP2\|CNTNAP5\|CREBBP\|DHCR7\|DLGAP2\|DMD\|DOCK4\|DPP10\|DPP6\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GABRG1\|GNA14\|GRIN2B\|GRPR\|HOXA1\|HPRT1\|IMMP2L\|KATNAL2\|KCTD13\|KDM5C\|KIRREL3\|KLHL3\|L1CAM\|LAMC3\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|NEGR1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRXN1\|NSD1\|NTNG1\|OPHN1\|PAFAH1B1\|PCDH19\|PCDH9\|PDE10A\|PHF6\|PIP5K1B\|PNKP\|PON3\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RBFOX1\|RELN\|RPL10\|SATB2\|SCN1A\|SCN2A\|SHANK2\|SHANK3\|SLC6A4\|SLC9A6\|SLC9A9\|SMC1A\|SMG6\|SNRPN\|SOX5\|SPAST\|ST7\|STK3\|TCF4\|TSC1\|TSC2\|UBE3A\|VPS13B\|ZEB2\|ZNF507\|ZNF804A\|ZNHIT6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509367.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509367 | CASK\|OPHN1\|RARS2\|SEPSECS\|TSEN2\|TSEN34\|TSEN54\|VRK1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509368.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509368 | ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ATP6V0A2\|B3GALTL\|B4GALT1\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|DDOST\|DHDDS\|DOLK\|DPAGT1\|DPM1\|DPM3\|GNE\|MAGT1\|MGAT2\|MOGS\|MPDU1\|MPI\|PMM2\|RFT1\|RPN2\|SEC23B\|SLC35A1\|SLC35C1\|SRD5A3\|TUSC3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509399.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509399 | ABAT\|ABCB1\|ABCC8\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCS1L\|BRAF\|BTD\|BUB1B\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COG1\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|EFHC1\|EFHC2\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HCN1\|HCN4\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|IDS\|IDUA\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIG4\|LRPPRC\|MAGI2\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MLC1\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDSS1\|PDSS2\|PEX1\|PEX12\|PEX14\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PHF6\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN10A\|SCN1A\|SCN1B\|SCN2A\|SCN2B\|SCN3A\|SCN3B\|SCN4A\|SCN4B\|SCN5A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC17A5\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35C1\|SLC46A1\|SLC6A5\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRPX2\|STIL\|STXBP1\|SUMF1\|SUOX\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509426.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509426 | ACVR1\|BEST1\|CA4\|CANT1\|COL18A1\|CYP1B1\|FOXC1\|ISPD\|LMX1B\|LOXL1\|LTBP2\|MTHFR\|MYOC\|NTF4\|OPA1\|OPTN\|PAX6\|PITX3\|POMT1\|RPS19\|RRM2B\|SBF2\|SLC4A4\|TTR\|WDR36 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509427.10 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509427 | AIP\|APC\|ATM\|ATR\|AXIN2\|BAP1\|BARD1\|BLM\|BMPR1A\|BRCA1\|BRCA2\|BRIP1\|BUB1B\|CDH1\|CDK4\|CDKN1B\|CDKN2A\|CHEK2\|CTNNB1\|CYLD\|DDB2\|DICER1\|EGFR\|EGLN1\|EPCAM\|ERCC2\|ERCC3\|ERCC4\|ERCC5\|EXO1\|EXT1\|EXT2\|FANCA\|FANCB\|FANCC\|FANCD2\|FANCE\|FANCF\|FANCG\|FANCI\|FANCL\|FANCM\|FH\|FLCN\|GALNT12\|GPC3\|HOXB13\|HRAS\|KIF1B\|KIT\|MAX\|MC1R\|MEN1\|MET\|MITF\|MLH1\|MPL\|MRE11A\|MSH2\|MSH3\|MSH6\|MUTYH\|NBN\|NF1\|NF2\|PALB2\|PDGFRA\|PICALM\|PMS1\|PMS2\|POLD1\|PRKAR1A\|PRKDC\|PRSS1\|PTCH1\|PTEN\|PTPN11\|RAD50\|RAD51\|RAD51C\|RAD51D\|RB1\|RBBP8\|RBM15\|RECQL4\|RET\|ROBO2\|SBDS\|SDHA\|SDHAF2\|SDHB\|SDHC\|SDHD\|SLX4\|SMAD4\|SMARCB1\|STK11\|SUFU\|TERT\|TMEM127\|TP53\|TSC1\|TSC2\|TSHR\|TYR\|VHL\|WRN\|WT1\|XPA\|XPC\|XRCC2\|XRCC3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509430.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509430 | ACTB\|ACTG1\|ARX\|DCX\|FKRP\|FKTN\|LARGE\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|RELN\|TUBA1A\|VLDLR | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509431.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509431 | ABAT\|ACOX1\|ALDH3A2\|ARSA\|ASPA\|CSF1R\|DARS2\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|FAM126A\|GFAP\|GJC2\|HEPACAM\|HSPD1\|HTRA1\|LMNB1\|MLC1\|NOTCH3\|PLP1\|PSAP\|PTEN\|SCP2\|SLC25A12 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509432.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509432 | ACAD9\|ADCK3\|APTX\|ATP5E\|ATPAF2\|BCS1L\|COQ2\|COQ9\|COX10\|COX15\|COX6B1\|DARS2\|DGUOK\|DLAT\|DLD\|DNM1L\|ETFA\|ETFB\|ETFDH\|ETHE1\|FBP1\|FH\|FOXRED1\|G6PC\|GFM1\|GYS2\|ISCU\|LRPPRC\|MRPS16\|MRPS22\|NDUFA11\|NDUFAF1\|NDUFAF3\|NDUFAF4\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|PC\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|POLG\|PUS1\|RRM2B\|SCO2\|SLC25A3\|SLC25A4\|SUCLA2\|SUCLG1\|TAZ\|TK2\|TMEM70\|TRMU\|TSFM\|TUFM\|TYMP\|UQCRB\|YARS2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509436.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509436 | ABCC8\|ACY1\|ADAMTSL2\|ADSL\|AGA\|ALDH4A1\|ALDH5A1\|ALDH7A1\|AMT\|ANTXR2\|ARG1\|ARSA\|ARSB\|ASAH1\|ASPA\|ATP13A2\|BTD\|CLN3\|CLN5\|CLN6\|CLN8\|COL11A2\|COL2A1\|CTNS\|CTSA\|CTSC\|CTSD\|CTSK\|DHCR7\|DNAJC5\|DPYD\|DYM\|ETFA\|ETFB\|ETFDH\|FH\|FOLR1\|FUCA1\|GAA\|GALC\|GALNS\|GAMT\|GBA\|GCDH\|GCSH\|GLA\|GLB1\|GLDC\|GM2A\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GUSB\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|IDS\|IDUA\|L2HGDH\|LAMA2\|LAMP2\|LIPA\|LMBRD1\|MAN2B1\|MANBA\|MCOLN1\|MFSD8\|MOCS1\|MOCS2\|NAGA\|NAGLU\|NEU1\|NPC1\|NPC2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX26\|PEX3\|PEX5\|PEX6\|PGK1\|PHYH\|PPT1\|PRODH\|PSAP\|QDPR\|RAI1\|SGSH\|SLC17A5\|SLC25A15\|SLC46A1\|SMPD1\|SUMF1\|SUOX\|TCF4\|TPP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509441.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509441 | ABCA4\|C2\|C3\|CFB\|CFH\|CFI\|CNGB3\|CST3\|CX3CR1\|EFEMP1\|ELOVL4\|ERCC6\|FBLN5\|HMCN1\|HTRA1\|PRPH2\|RAX2\|RLBP1\|RPGR\|TLR4 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509442.11 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509442 | ABCC6\|ABCD1\|ABCG5\|ACAT1\|ACOX1\|ACSL4\|ACY1\|ADAR\|ADSL\|AFF2\|AFP\|AGL\|AGT\|AGTR2\|AHI1\|AIFM1\|ALDH18A1\|ALDH4A1\|ALG11\|ALG12\|ALG6\|ALX4\|AMER1\|AP1S1\|AP1S2\|AP3B1\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|APOB\|AQP7\|AR\|ARG1\|ARHGEF6\|ARID1A\|ARID1B\|ARX\|ASPM\|ASS1\|ATL1\|ATM\|ATP13A2\|ATP1A2\|ATP6AP2\|ATP7A\|ATRX\|AUH\|AVP\|AVPR2\|BBS9\|BCS1L\|BIN1\|BRCA2\|BRIP1\|BRWD3\|BUB1B\|CACNG2\|CAMTA1\|CANT1\|CASK\|CBS\|CC2D1A\|CC2D2A\|CCDC88C\|CDH15\|CDKL5\|CDKN1C\|CEP290\|CEP41\|CEP57\|CHD7\|CHRNA4\|CLN3\|CNTNAP2\|COG5\|COG7\|COL1A2\|CP\|CPA6\|CPS1\|CRADD\|CRBN\|CTC1\|CTNNB1\|CTSA\|CUL4B\|CYB5R3\|CYP27A1\|D2HGDH\|DARS2\|DBT\|DHCR24\|DHCR7\|DIP2B\|DLG3\|DMD\|DPYD\|DYNC1H1\|DYRK1A\|EBP\|EFNB1\|EHMT1\|ELOVL4\|ERCC2\|ERCC3\|ERCC5\|ERCC6\|ERCC8\|F5\|FAM126A\|FANCG\|FBLN5\|FBN1\|FBN2\|FGD1\|FGF14\|FGFR1\|FGFR2\|FGFR3\|FKRP\|FKTN\|FMR1\|FOXG1\|FOXP1\|FTO\|FTSJ1\|G6PC3\|GABRG2\|GALE\|GAMT\|GAN\|GBA\|GBE1\|GCK\|GDI1\|GFAP\|GFM1\|GHR\|GLI3\|GLRA1\|GLUL\|GLYCTK\|GM2A\|GNAS\|GNPAT\|GNPTAB\|GNPTG\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|GRM1\|GSS\|GUSB\|GYS2\|HAX1\|HDAC4\|HDAC8\|HEPACAM\|HEXB\|HOXD10\|HPD\|HSD17B10\|HSPD1\|HUWE1\|IDS\|IGBP1\|IGF1\|IGF1R\|IL1RAPL1\|INSR\|IQSEC2\|IRX5\|ITGA7\|KCNJ10\|KCNJ11\|KCNK9\|KCNQ2\|KCTD7\|KDM5C\|KIF11\|KIF1A\|KIF21A\|KIF5A\|KIF7\|KIRREL3\|KRAS\|L1CAM\|LAMA2\|LAMP2\|LARGE\|LBR\|LHX3\|LIG4\|LMBRD1\|LRP5\|LYST\|MAGT1\|MAN1B1\|MAN2B1\|MANBA\|MAPT\|MAT1A\|MBD5\|MBTPS2\|MCCC1\|MCCC2\|MCOLN1\|MCPH1\|MECP2\|MED17\|MED23\|MEF2C\|MFSD8\|MGAT2\|MKKS\|MMADHC\|MOCS2\|MPI\|MPZ\|MRAP\|MTFMT\|MTHFR\|MTR\|MYCN\|MYO5A\|MYO7A\|NAGA\|NBN\|NDP\|NDUFA1\|NDUFAF5\|NDUFS1\|NF1\|NGF\|NHEJ1\|NHP2\|NIPBL\|NLGN3\|NPC1\|NPC2\|NPHP3\|NRXN1\|NSDHL\|NSUN2\|OFD1\|OPHN1\|ORC1\|PAFAH1B1\|PAH\|PAK3\|PAX6\|PCDH19\|PCNT\|PDE4D\|PDHX\|PDSS1\|PEX7\|PGK1\|PHF8\|PHKA2\|PHKG2\|PIGL\|PIGO\|PIGV\|PLA2G6\|PLP1\|POMGNT1\|POMT1\|POMT2\|POU1F1\|PPOX\|PQBP1\|PRICKLE1\|PRKAR1A\|PRSS12\|PTEN\|PTPN11\|PYCR1\|PYGL\|RAB39B\|RAB40AL\|RAI1\|RAPSN\|RBBP8\|RBM10\|RFX6\|RPGRIP1L\|RPS6KA3\|SACS\|SAMHD1\|SATB2\|SCN1A\|SCN8A\|SDCCAG8\|SGCA\|SGSH\|SHANK2\|SHANK3\|SHROOM4\|SIL1\|SLC16A2\|SLC20A2\|SLC25A12\|SLC25A13\|SLC25A15\|SLC2A1\|SLC2A2\|SLC35C1\|SLC46A1\|SLC4A4\|SLC5A2\|SLC5A5\|SLC6A4\|SLC6A8\|SLC7A7\|SLC9A6\|SLX4\|SMARCA4\|SMARCB1\|SMC1A\|SMS\|SNIP1\|SOBP\|SOX10\|SOX2\|SOX3\|SPR\|SPTAN1\|SPTLC1\|SRD5A3\|SRPX2\|ST3GAL3\|STAT5B\|STRA6\|STX11\|STXBP1\|SUCLG1\|SYNGAP1\|SYP\|SYT14\|TBC1D24\|TBCE\|TBX1\|TECR\|TGIF1\|TH\|THRB\|TINF2\|TMCO1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPH2\|TPK1\|TRAPPC9\|TRHR\|TSC1\|TSC2\|TSHR\|TSPAN7\|TTC37\|TTR\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|TUSC3\|TWIST1\|UBE2A\|UBE3A\|UPB1\|UPF3B\|UROC1\|USP9X\|VLDLR\|VPS13B\|WDR62\|WDR81\|WRN\|XIST\|XPNPEP3\|ZBTB16\|ZBTB24\|ZDHHC9\|ZEB2\|ZFP57\|ZFYVE26\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | | Not reported | Not reported
GTR000509443.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509443 | ALDH7A1\|ARX\|ATP1A2\|CACNA1A\|CDKL5\|FOLR1\|FOXG1\|GAMT\|KCNQ2\|MECP2\|PCDH19\|PHGDH\|PNPO\|POLG\|PPT1\|SCN1A\|SLC2A1\|STXBP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509444.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509444 | ACAD9\|ACADL\|ACADM\|ACADVL\|AGL\|C10orf2\|CPT1B\|CPT2\|GAA\|GYS1\|HADHA\|HADHB\|OPA1\|OPA3\|PFKM\|PGAM2\|PGM1\|PHKA1\|POLG\|POLG2\|RRM2B\|SUCLA2\|TK2\|TYMP | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509446.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509446 | C10orf2\|DGUOK\|MPV17\|POLG\|POLG2\|RRM2B\|SLC25A4\|SUCLA2\|SUCLG1\|TK2\|TYMP | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509449.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509449 | AKT3\|BUB1B\|CASK\|CDK5RAP2\|CENPJ\|CEP135\|CEP152\|CEP63\|DNM1L\|EFTUD2\|IER3IP1\|KIF11\|LIG4\|MCPH1\|MED17\|MRE11A\|MSMO1\|NDE1\|NHEJ1\|NR2E1\|PAFAH1B1\|PCNT\|PNKP\|POMT1\|PQBP1\|RARS2\|SLC25A19\|STIL\|TSEN2\|TSEN34\|TSEN54\|TUBB2B\|TUBGCP6\|VRK1\|WDR62 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509453.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509453 | CLN3\|CLN5\|CLN6\|CLN8\|CTSD\|DNAJC5\|KCTD7\|MFSD8\|PPT1\|TPP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509454.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509454 | ACTA1\|AMPD1\|AMPD3\|ANO5\|CAPN3\|CAV3\|COL6A1\|COL6A2\|COL6A3\|DES\|DMD\|DYSF\|EMD\|FKRP\|FKTN\|ITGA7\|LAMA2\|LARGE\|LMNA\|MYOT\|NEB\|PEX1\|PEX12\|PEX14\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PLEC\|PMM2\|POMGNT1\|POMT1\|POMT2\|RYR1\|RYR2\|SEPN1\|SGCA\|SGCB\|SGCD\|SGCE\|SGCG\|SIL1\|TCAP\|TNNI2\|TNNT1\|TPM2\|TPM3\|TRIM32\|TTN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509461.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509461 | ATR\|CDC6\|CDT1\|CENPJ\|CEP152\|CEP63\|ORC1\|ORC4\|ORC6\|PCNT\|RBBP8\|RNU4ATAC | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509462.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509462 | ARX\|ATRX\|CAV1\|CDKL5\|CNTNAP2\|FOXG1\|MECP2\|MED17\|MEF2C\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|TRAPPC9\|UBE3A\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509491.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509491 | GPR56\|KIAA1279\|SRPX2\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509492.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509492 | HESX1\|OTX2\|PAX6\|PROP1\|SOX2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510709.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510709 | ACTB\|ACTG1\|ATP2B2\|ATP6V1B1\|BCS1L\|BSND\|CATSPER2\|CCDC50\|CDH23\|CLDN14\|CLRN1\|COCH\|COL11A2\|COL9A3\|CRYM\|DFNA5\|DFNB31\|DFNB59\|DIAPH1\|DSPP\|EDN3\|EDNRB\|ERCC2\|ERCC3\|ESPN\|ESRRB\|EYA1\|EYA4\|FGF3\|FOXI1\|GATA3\|GIPC3\|GJA1\|GJB2\|GJB3\|GJB6\|GPR98\|GPSM2\|GRHL2\|GRXCR1\|GSTP1\|HGF\|ILDR1\|JAG1\|KCNE1\|KCNJ10\|KCNQ1\|KCNQ4\|LHFPL5\|LHX3\|LOXHD1\|LRTOMT\|MARVELD2\|MIR96\|MITF\|MSRB3\|MTAP\|MYH14\|MYH9\|MYO15A\|MYO1A\|MYO1C\|MYO1F\|MYO3A\|MYO6\|MYO7A\|OTOA\|OTOF\|PAX3\|PCDH15\|PDZD7\|PMP22\|POU3F4\|POU4F3\|PRPS1\|PTPRQ\|RDX\|SERPINB6\|SIX1\|SLC17A8\|SLC26A4\|SLC26A5\|SLC4A11\|SMPX\|SNAI2\|SOX10\|SPINK5\|TBL1X\|TCF21\|TECTA\|TIMM8A\|TJP2\|TMC1\|TMIE\|TMPRSS3\|TMPRSS5\|TPRN\|TRIOBP\|TRMU\|USH1C\|USH1G\|USH2A\|WFS1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510870.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510870 | DHFR\|FOLR1\|FPGS\|MTHFD1\|MTHFD1L\|MTHFS\|PTS\|SHMT1\|SLC19A1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510871.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510871 | AKAP9\|ANK2\|CACNA1C\|CACNB2\|CALR3\|CASQ2\|CAV3\|CSRP3\|DES\|DSC2\|DSG2\|DSP\|DTNA\|EYA4\|FBN1\|FBN2\|FKTN\|GJA5\|GPD1L\|JPH2\|JUP\|KCNA5\|KCNE1\|KCNE2\|KCNE3\|KCNH2\|KCNJ2\|KCNQ1\|LAMP2\|LDB3\|LMNA\|LRP6\|MYBPC3\|MYH6\|MYH7\|MYL2\|MYL3\|MYLK2\|MYOZ2\|NEXN\|NPPA\|PKP2\|PLN\|PRKAG2\|PSEN1\|PSEN2\|RBM20\|RYR2\|SCN1B\|SCN3B\|SCN4B\|SCN5A\|SGCD\|SLC25A4\|SNTA1\|TAZ\|TCAP\|TGFB3\|TGFBR2\|TMEM43\|TMPO\|TNNC1\|TNNI3\|TNNT2\|TPM1\|TTN\|VCL | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510909.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510909 | ABCD1\|ACOX1\|ATL1\|BSCL2\|CYP7B1\|FA2H\|KIAA0196\|KIF1A\|KIF5A\|L1CAM\|NIPA1\|OPA3\|PLP1\|REEP1\|RTN2\|SLC16A2\|SLC33A1\|SPAST\|SPG11\|SPG20\|SPG21\|SPG7\|ZFYVE26\|ZFYVE27 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510915.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510915 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ABCD3\|ACACA\|ACACB\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACLY\|ACO2\|ACSF3\|ACSL4\|ACSL5\|ACSM3\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AGXT2\|AIFM1\|AK2\|AKAP10\|AKR7A2\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|AS3MT\|ASS1\|ATIC\|ATP10D\|ATP5E\|ATP5SL\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BAX\|BCAT1\|BCAT2\|BCKDHA\|BCKDHB\|BCL2\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDC42BPB\|CDKL5\|CFTR\|CHAT\|CHDH\|CHRNA4\|CHRNB2\|CISD2\|CKM\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CLYBL\|CNR1\|COA5\|COMT\|COQ2\|COQ4\|COQ5\|COQ6\|COQ9\|COX10\|COX15\|COX4I1\|COX4I2\|COX6B1\|COX7A2\|CPOX\|CPS1\|CPT1A\|CPT1B\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDAH1\|DDC\|DECR1\|DGUOK\|DHODH\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNAJC5\|DNM1L\|DTNBP1\|EARS2\|ECI1\|ECSIT\|ELAC2\|ELN\|ENO1\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FAAH\|FARS2\|FASN\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FPGS\|FTH1\|FXN\|G6PC\|G6PD\|GAD1\|GAD2\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLO1\|GLRA1\|GLRX5\|GLS\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPAM\|GPD1\|GPD2\|GPI\|GPX1\|GPX4\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HARS\|HARS2\|HCCS\|HIBCH\|HIGD2A\|HK1\|HK2\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B1\|HSD3B2\|HSPA9\|HSPB7\|HSPD1\|HTRA2\|HTT\|IDE\|IDH1\|IDH2\|IDH3B\|IMMP2L\|IMMT\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|KYNU\|L2HGDH\|LARS2\|LDHA\|LDHB\|LETM1\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MAOB\|MARS2\|MAVS\|MCCC1\|MCCC2\|MCEE\|MDH1\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MGLL\|MGST3\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCOS\|MOCS1\|MOCS2\|MOGS\|MRPL3\|MRPL48\|MRPS16\|MRPS22\|MRRF\|MTCH2\|MTFMT\|MTHFD1\|MTHFD1L\|MTHFS\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA4\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB1\|NDUFB3\|NDUFB6\|NDUFB9\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NFU1\|NIPSNAP1\|NIPSNAP3A\|NLRX1\|NME1\|NOS3\|NPL\|NRXN1\|NTHL1\|NUBPL\|OAT\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PACRG\|PAH\|PAK7\|PANK2\|PARK2\|PARL\|PARP1\|PC\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PKLR\|PMPCA\|PNKD\|PNMT\|POLG\|POLG2\|POLRMT\|PPARGC1A\|PPARGC1B\|PPOX\|PPT1\|PREPL\|PRODH\|PTGES2\|PTS\|PUS1\|PYCR1\|QDPR\|RAB11FIP5\|RARS2\|REEP1\|RNASEL\|RPL35A\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SHMT1\|SIRT1\|SIRT3\|SIRT5\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A39\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|TACO1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TFAM\|TFB1M\|TIMM44\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOMM40\|TOP1MT\|TP53\|TPH2\|TPI1\|TPP1\|TRMU\|TSFM\|TSPO\|TST\|TTC19\|TUFM\|TXN2\|TXNRD2\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|USP24\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510916.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510916 | ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|AP1S2\|ARHGEF6\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|EBP\|FAAH2\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|GSPT2\|HCCS\|HDAC8\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|L1CAM\|LAMP2\|MAGT1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RAB40AL\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SRPX2\|SYN1\|SYP\|TAF1\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|USP9X\|WDR13\|ZCCHC12\|ZDHHC15\|ZDHHC9\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000514645.1 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 514645 | ACAD9\|ACADL\|ACADM\|ACADS\|ACADVL\|CPT1A\|CPT1B\|CPT2\|ETFA\|ETFB\|ETFDH\|GLUD1\|HADH\|HADHA\|HADHB\|HMGCL\|HMGCS2\|HSD17B10\|LPIN1\|SLC22A5\|SLC25A20\|TAZ | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cell culture\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000310785.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 310785 | OPHN1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000324198.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 324198 | MEF2C | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000324273.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 324273 | CASK | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000325792.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 325792 | WDR62 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000332148.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 332148 | GRIN2A | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500125.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500125 | CASK | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500138.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500138 | MEF2C | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500153.5 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500153 | ARHGEF9\|ARX\|CDKL5\|EFHC1\|GRIN2A\|KCNQ2\|PCDH19\|PLCB1\|PNKP\|POLG\|SCN1A\|SCN2A\|SCN8A\|SLC25A22\|SLC2A1\|SPTAN1\|ST3GAL3\|ST3GAL5\|STXBP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000500154.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500154 | ALG6\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|C12orf57\|CA8\|CC2D1A\|CNTNAP2\|CRBN\|D2HGDH\|DDHD2\|ERLIN2\|GRIK2\|IDH2\|KCNJ10\|L2HGDH\|LINS\|LRP2\|MAN1B1\|MED23\|NRXN1\|NSUN2\|PCNT\|PRSS12\|SLC25A1\|ST3GAL3\|STXBP1\|TECR\|TRAPPC9\|TUSC3\|VLDLR\|VPS13B\|ZC3H14\|ZNF526 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500155.3 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500155 | ACSL4\|AFF2\|AGTR2\|AP1S2\|ARHGEF6\|ARHGEF9\|ARX\|ATP6AP2\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDKL5\|CLIC2\|CUL4B\|DCX\|DLG3\|EIF2S3\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GRIA3\|HCFC1\|HPRT1\|HSD17B10\|HUWE1\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|KLF8\|L1CAM\|MAGT1\|MAOA\|MECP2\|MED12\|MID1\|NAA10\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|PAK3\|PCDH19\|PDHA1\|PHF6\|PHF8\|PLP1\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC6A8\|SLC9A6\|SMC1A\|SMS\|SRPX2\|SYN1\|SYP\|TSPAN7\|UBE2A\|UPF3B\|ZDHHC15\|ZDHHC9\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500162.5 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500162 | ACSL4\|AFF2\|AGTR2\|ALG6\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARHGEF6\|ARHGEF9\|ARID1B\|ARX\|ATP6AP2\|ATRX\|BCOR\|BRWD3\|C12orf57\|CA8\|CACNG2\|CASK\|CC2D1A\|CCDC22\|CDH15\|CDKL5\|CLIC2\|CNTNAP2\|CRBN\|CTCF\|CTNNB1\|CUL4B\|D2HGDH\|DCX\|DDHD2\|DLG3\|DYNC1H1\|DYRK1A\|EHMT1\|EIF2S3\|EPB41L1\|ERLIN2\|FLNA\|FMR1\|FOXG1\|FOXP1\|FRMPD4\|FTSJ1\|GATAD2B\|GDI1\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|HCFC1\|HPRT1\|HSD17B10\|HUWE1\|IDH2\|IGBP1\|IL1RAPL1\|IQSEC2\|KCNJ10\|KDM5C\|KIAA2022\|KIF1A\|KIRREL3\|KLF8\|L1CAM\|L2HGDH\|LINS\|LRP2\|MAGT1\|MAN1B1\|MAOA\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MID1\|NAA10\|NHS\|NLGN3\|NLGN4X\|NRXN1\|NRXN2\|NSDHL\|NSUN2\|OCRL\|OFD1\|OPHN1\|PACS1\|PAK3\|PCDH19\|PCNT\|PDHA1\|PHF6\|PHF8\|PLP1\|PQBP1\|PRPS1\|PRSS12\|PTCHD1\|RAB39B\|RAI1\|RPS6KA3\|SCN2A\|SHANK2\|SHANK3\|SHROOM4\|SLC16A2\|SLC25A1\|SLC6A8\|SLC9A6\|SMARCA4\|SMC1A\|SMS\|SOBP\|SRPX2\|ST3GAL3\|STXBP1\|SYN1\|SYNGAP1\|SYP\|TCF4\|TECR\|TRAPPC9\|TSPAN7\|TUBA1A\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZC3H14\|ZDHHC15\|ZDHHC9\|ZEB2\|ZNF407\|ZNF41\|ZNF526\|ZNF674\|ZNF711\|ZNF81 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500166.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500166 | OPHN1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500289.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500289 | ACTB\|ACTG1\|ARX\|DCX\|FKRP\|FKTN\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|RELN\|TUBA1A\|VLDLR | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000501098.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 501098 | ARX\|ATRX\|CDKL5\|CNTNAP2\|DYRK1A\|EHMT1\|FOLR1\|FOXG1\|MBD5\|MECP2\|MEF2C\|NRXN1\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|UBE3A\|ZEB2 | Deletion/duplication analysis | Comparative Genomic Hybridization | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000501100.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 501100 | DCAF17 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000501110.4 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 501110 | ARX\|ATRX\|CDKL5\|CNTNAP2\|DYRK1A\|EHMT1\|FOLR1\|FOXG1\|MBD5\|MECP2\|MEF2C\|NRXN1\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000506307.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 506307 | CHKB\|COL6A1\|COL6A2\|COL6A3\|DAG1\|DPM2\|DPM3\|FKRP\|FKTN\|ISPD\|ITGA7\|LAMA2\|LARGE\|LMNA\|POMGNT1\|POMGNT2\|POMT1\|POMT2\|RYR1\|SEPN1\|TMEM5 | Deletion/duplication analysis | Microarray | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000506308.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 506308 | CHKB\|COL6A1\|COL6A2\|COL6A3\|DAG1\|DPM2\|DPM3\|FKRP\|FKTN\|ISPD\|ITGA7\|LAMA2\|LARGE\|LMNA\|POMGNT1\|POMGNT2\|POMT1\|POMT2\|RYR1\|SEPN1\|TMEM5 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000506315.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 506315 | DCAF17 | Deletion/duplication analysis | Microarray | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000506321.3 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 506321 | ANO5\|CAPN3\|CAV3\|DAG1\|DES\|DNAJB6\|DYSF\|FKRP\|FKTN\|FLNC\|GAA\|LMNA\|MYOT\|PLEC\|POMGNT1\|POMT1\|POMT2\|SGCA\|SGCB\|SGCD\|SGCG\|TCAP\|TRIM32\|TTN | Deletion/duplication analysis | Microarray | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000506322.3 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 506322 | ANO5\|CAPN3\|CAV3\|DAG1\|DES\|DNAJB6\|DYSF\|FKRP\|FKTN\|FLNC\|GAA\|LMNA\|MYOT\|PLEC\|POMGNT1\|POMT1\|POMT2\|SGCA\|SGCB\|SGCD\|TCAP\|TRIM32\|TTN | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000506323.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 506323 | ATP13A2\|C19orf12\|CP\|DCAF17\|FA2H\|FTL\|PANK2\|PLA2G6\|WDR45 | Deletion/duplication analysis | Microarray | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000506324.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 506324 | ATP13A2\|C19orf12\|CP\|DCAF17\|FA2H\|FTL\|PANK2\|PLA2G6\|WDR45 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000507771.3 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 507771 | ARFGEF2\|ASPM\|ATR\|ATRX\|CASC5\|CASK\|CDC6\|CDK5RAP2\|CDKL5\|CDT1\|CENPJ\|CEP135\|CEP152\|CEP63\|FOXG1\|MCPH1\|MECP2\|MED17\|NDE1\|ORC1\|ORC4\|ORC6\|PCNT\|PNKP\|RAB3GAP1\|RBBP8\|SLC25A19\|SLC2A1\|SLC9A6\|STAMBP\|STIL\|TCF4\|TSEN2\|TSEN34\|TSEN54\|UBE3A\|WDR62\|ZEB2\|ZNF335 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000508585.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 508585 | ACTB\|ACTG1\|ARX\|DCX\|FKRP\|FKTN\|GPR56\|KIAA1279\|LAMC3\|LARGE\|OCLN\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|RAB18\|RAB3GAP1\|RAB3GAP2\|RELN\|RTTN\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|VLDLR\|WDR62 | Deletion/duplication analysis | Microarray | Buccal swab\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000508586.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 508586 | ACTB\|ACTG1\|ARX\|DCX\|FKRP\|FKTN\|GPR56\|KIAA1279\|LAMC3\|LARGE\|OCLN\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|RAB18\|RAB3GAP1\|RAB3GAP2\|RELN\|RTTN\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|VLDLR\|WDR62 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509252.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 509252 | CHD7\|DHODH\|EFTUD2\|MYCN\|POLR1C\|POLR1D\|SF3B4\|TCOF1 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | No
GTR000281976.1 | Greenwood Genetic Center Diagnostic Laboratories Greenwood Genetic Center South Carolina 42D0689473 281976 | MED12 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Saliva\|Skin | Decline to answer | Yes
GTR000328483.1 | Greenwood Genetic Center Diagnostic Laboratories Greenwood Genetic Center South Carolina 42D0689473 328483 | CASK | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Saliva\|Skin | Decline to answer | No
GTR000502023.1 | Greenwood Genetic Center Diagnostic Laboratories Greenwood Genetic Center South Carolina 42D0689473 502023 | ACSL4 | Mutation scanning of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Saliva\|Skin | Decline to answer | Yes
GTR000327662.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 327662 | AP1S2\|ARX\|ASPM\|ATRX\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CBL\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DCX\|DHCR7\|DMD\|EHMT1\|ERCC6\|ERCC8\|FGD1\|FGFR1\|FGFR2\|FGFR3\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|HDAC8\|HOXA1\|HPRT1\|HRAS\|KDM5C\|KMT2D\|KRAS\|L1CAM\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|MKKS\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCH1\|PTEN\|PTPN11\|RAB39B\|RAD21\|RAF1\|RAI1\|RELN\|RPGRIP1L\|RPS6KA3\|SCN1A\|SHANK2\|SHANK3\|SHOC2\|SLC2A1\|SLC6A4\|SLC9A6\|SMC1A\|SMC3\|SOS1\|SPRED1\|TCF4\|TSC1\|TSC2\|TUBA1A\|UBE3A\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | No | No
GTR000515046.3 | Illumina Clinical Services Laboratory Illumina California 05D1092911 515046 | Not reported | Not reported | Not reported | Not reported | Not reported | NOT REPORTED
GTR000514956.1 | Invitae — California 05D2040778 514956 | MED12\|UPF3B | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000506862.1 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 506862 | GDI1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000509437.3 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 509437 | MEF2C | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000500546.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500546 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000500583.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500583 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000501524.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501524 | ARX\|CDKL5\|MEF2C\|SLC25A22\|SRPX2\|STXBP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501565.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501565 | MEF2C | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501566.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501566 | MEF2C | Sequence analysis of the entire coding region | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501567.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501567 | MEF2C | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501568.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501568 | MEF2C | Targeted variant analysis | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501569.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501569 | CASK | Sequence analysis of the entire coding region | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501570.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501570 | CASK | Targeted variant analysis | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501710.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501710 | SRPX2 | Sequence analysis of the entire coding region | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501714.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501714 | SRPX2 | Targeted variant analysis | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000502794.3 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 502794 | FGFR2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000503333.2 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503333 | FGFR2 | Deletion/duplication analysis | Microarray | Not reported | Decline to answer | No
GTR000503358.3 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503358 | PAX6 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000503360.2 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503360 | PAX6 | Deletion/duplication analysis | Microarray | Not reported | Decline to answer | No
GTR000505116.2 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 505116 | EFTUD2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000505118.2 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 505118 | EFTUD2 | Deletion/duplication analysis | Microarray | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000509671.1 | Molecular Genetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 509671 | HSD17B10 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Decline to answer | Yes
GTR000507942.2 | Pittsburgh Cytogenetics Laboratory University of Pittsburgh Medical Center Pennsylvania 39D0673863 507942 | ABCB7\|ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|ALAS2\|ALG13\|AMELX\|AMER1\|AP1S2\|AR\|ARHGEF6\|ARHGEF9\|ARSE\|ARX\|ATP2B3\|ATP6AP2\|ATP7A\|ATRX\|AVPR2\|BCOR\|BRWD3\|BTK\|CACNA1F\|CASK\|CDKL5\|CFP\|CHM\|CHRDL1\|CLCN5\|CLIC2\|COL4A5\|COX7B\|CSF2RA\|CYBB\|DCX\|DKC1\|DLG3\|DMD\|EBP\|EDA\|EFNB1\|EMD\|F8\|F9\|FAM58A\|FANCB\|FHL1\|FLNA\|FTSJ1\|G6PD\|GATA1\|GDI1\|GJB1\|GK\|GLA\|GPR143\|GRIA3\|HCCS\|HCFC1\|HDAC8\|HPRT1\|HSD17B10\|IDS\|IGBP1\|IGSF1\|IKBKG\|IL1RAPL1\|IL2RG\|KAL1\|KDM5C\|KDM6A\|L1CAM\|LAMP2\|MAGT1\|MAMLD1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NHS\|NLGN3\|NLGN4X\|NR0B1\|NSDHL\|OCRL\|OFD1\|OPHN1\|OPN1MW\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PHKA1\|PHKA2\|PIGA\|PLP1\|POLA1\|PORCN\|POU3F4\|PQBP1\|PRPS1\|RAB39B\|RAB40AL\|RBM10\|RP2\|RPGR\|RPL10\|RPS6KA3\|RS1\|SAT1\|SERPINA7\|SH2D1A\|SHOX\|SHROOM4\|SLC16A2\|SLC35A2\|SLC6A14\|SLC6A8\|SLC9A6\|SMPX\|SMS\|SOX3\|SRPX2\|SRY\|STS\|SYN1\|SYP\|TAF1\|TAZ\|TBX22\|TIMM8A\|TMLHE\|TRAPPC2\|TSPAN7\|UBA1\|UBE2A\|UBQLN2\|UPF3B\|VMA21\|WAS\|WDR45\|XIAP\|XK\|ZC4H2\|ZDHHC15\|ZDHHC9\|ZIC3\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniotic fluid\|Cell culture\|Chorionic villi\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | No
GTR000505136.7 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 505136 | B3GALNT2\|B3GNT1\|DAG1\|DPM1\|DPM3\|FKRP\|FKTN\|GMPPB\|GOSR2\|ISPD\|LARGE\|POMGNT1\|POMGNT2\|POMK\|POMT1\|POMT2\|ST3GAL4\|TMEM5 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000505633.4 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 505633 | B3GALNT2\|B3GNT1\|CHKB\|DAG1\|DPM1\|DPM3\|FKRP\|FKTN\|GMPPB\|GOSR2\|ISPD\|ITGA7\|LAMA2\|LARGE\|LMNA\|POMGNT1\|POMGNT2\|POMK\|POMT1\|POMT2\|ST3GAL4\|TMEM5 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000505638.3 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 505638 | B3GALNT2\|B3GNT1\|DAG1\|FKRP\|FKTN\|ISPD\|LARGE\|POMGNT1\|POMGNT2\|POMT1\|POMT2\|TMEM5 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000505640.4 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 505640 | ANO5\|CAPN3\|DYSF\|FKRP\|GMPPB\|SGCA\|SGCB\|SGCD\|SGCG\|TCAP\|TRAPPC11\|TRIM32\|TTN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000505780.2 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 505780 | FKTN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000505832.2 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 505832 | FKRP | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000506020.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 506020 | LARGE | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000506181.2 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 506181 | POMGNT1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000506182.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 506182 | POMT1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000506184.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 506184 | POMT2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000506404.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 506404 | CUL4B | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000506407.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 506407 | DYNC1H1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000507440.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 507440 | MED12 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000507448.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 507448 | HEPACAM | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000507451.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 507451 | OPHN1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000507700.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 507700 | EFTUD2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000507718.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 507718 | TRAPPC9 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000507719.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 507719 | TUSC3 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000508519.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 508519 | HDAC8 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000508763.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 508763 | GMPPB | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000509896.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 509896 | ARHGEF9\|ARX\|CDKL5\|CHD2\|EFHC1\|GABRA1\|GABRB3\|GABRG2\|GRIN2A\|MBD5\|MECP2\|MEF2C\|PCDH19\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SLC2A1\|SLC9A6\|SPTAN1\|STXBP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region\|Targeted variant analysis | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000510109.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 510109 | FGFR2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region\|Targeted variant analysis | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000501919.2 | Transgenomic Transgenomic Connecticut 07D0995237 501919 | AARS2\|AASS\|ABAT\|ABCB7\|ABCD1\|ABHD5\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADSB\|ACADVL\|ACAT1\|ACSF3\|ACSL4\|ADCK3\|AFG3L2\|AGXT\|AIFM1\|AIFM2\|AK2\|AKR1D1\|ALAS2\|ALDH18A1\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMACR\|AMT\|APEX2\|APTX\|ARG1\|ARMS2\|ASL\|ASS1\|ATL1\|ATM\|ATP5A1\|ATP5B\|ATP5C1\|ATP5D\|ATP5E\|ATP5F1\|ATP5G1\|ATP5G2\|ATP5G3\|ATP5I\|ATP5J\|ATP5O\|ATP7B\|ATPAF1\|ATPAF2\|ATPIF1\|ATXN10\|ATXN7\|AUH\|B4GALT1\|BCKDHA\|BCKDHB\|BCS1L\|BRAF\|BTD\|C10orf2\|C12orf65\|C14orf2\|CAPN3\|CARS2\|CAV3\|CDKL5\|CHKB\|CISD2\|CLN3\|CLN5\|CLN6\|CLN8\|CMC1\|COG1\|COG7\|COG8\|COQ2\|COQ3\|COQ4\|COQ6\|COQ7\|COQ9\|COX10\|COX11\|COX15\|COX17\|COX18\|COX19\|COX4I1\|COX4I2\|COX5A\|COX5B\|COX6A1\|COX6A2\|COX6B1\|COX6C\|COX7A1\|COX7A2\|COX7A2L\|COX7B\|COX7B2\|COX7C\|COX8A\|CPOX\|CPS1\|CPT1A\|CPT2\|CRLS1\|CRYAB\|CTNS\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYC1\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP27A1\|CYP27B1\|CYP7B1\|D2HGDH\|DARS2\|DBT\|DCX\|DECR1\|DGUOK\|DLAT\|DLD\|DLST\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DNM2\|DOLK\|DPAGT1\|DPM1\|DPM3\|EARS2\|ECSIT\|EIF2AK3\|ELOVL4\|ETFA\|ETFB\|ETFDH\|ETHE1\|FA2H\|FARS2\|FASTKD2\|FECH\|FGF14\|FH\|FOXG1\|FOXRED1\|FXN\|GAA\|GAD1\|GAMT\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLA\|GLDC\|GLRX5\|GLUD1\|GNPAT\|GPD2\|GPHN\|HADH\|HADHA\|HADHB\|HARS2\|HAX1\|HCCS\|HFE\|HK1\|HLCS\|HMGCL\|HMGCS2\|HSD17B10\|HSD3B2\|HSPD1\|IARS2\|IDH2\|ISCU\|ITPR1\|IVD\|KARS\|KCNC3\|KCNJ11\|KIAA0196\|KIAA0226\|KIF1B\|KIF5A\|LARS2\|LETM1\|LMBRD1\|LRPPRC\|MAOA\|MAPT\|MARS2\|MCCC1\|MCCC2\|ME2\|MECP2\|MFN2\|MFSD8\|MGAT2\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MPV17\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|MYH7\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA3\|NDUFA4\|NDUFA5\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAB1\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB1\|NDUFB10\|NDUFB11\|NDUFB2\|NDUFB3\|NDUFB4\|NDUFB5\|NDUFB6\|NDUFB7\|NDUFB8\|NDUFB9\|NDUFC1\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NEFL\|NIPA1\|NKX2-1\|NPC1\|NPC2\|NUBPL\|OAT\|OGDH\|OPA1\|OPA3\|OTC\|OXA1L\|OXCT1\|PAFAH1B1\|PANK2\|PARL\|PARS2\|PC\|PCCA\|PCCB\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX13\|PHB\|PHYH\|PLP1\|PMM2\|PNKD\|PNPLA2\|PNPLA3\|POLG\|POLG2\|PPM1B\|PPOX\|PPT1\|PREPL\|PRKCG\|PRODH\|PUS1\|PWAR1\|RARS2\|REEP1\|RFT1\|RMRP\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RRM2B\|RYR1\|SAMHD1\|SARS2\|SCN1A\|SCO1\|SCO2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SGCD\|SLC12A3\|SLC16A2\|SLC19A2\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A16\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC29A3\|SLC2A1\|SLC2A10\|SLC33A1\|SLC35A1\|SLC35C1\|SLC3A1\|SLC52A1\|SLC6A8\|SLC7A9\|SOD1\|SPAST\|SPG11\|SPG20\|SPG7\|SPTBN2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TACO1\|TARS2\|TAZ\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOP1MT\|TPM2\|TPP1\|TRMU\|TSFM\|TTBK2\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCR10\|UQCR11\|UQCRB\|UQCRC1\|UQCRC2\|UQCRFS1\|UQCRH\|UQCRQ\|UROS\|USMG5\|VARS2\|WARS2\|WFS1\|XDH\|XPNPEP3\|YARS2\|ZFYVE26 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000509336.2 | Transgenomic Transgenomic Connecticut 07D0995237 509336 | ABAT\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDK\|BCS1L\|BRAF\|BTD\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCDC88C\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX10\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EOMES\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LRPPRC\|MAGI2\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFAF6\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHLRC1\|NIPBL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RBFOX1\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC4A10\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|STIL\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VDAC1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000245064.4 | University of Iowa Diagnostic Laboratories University of Iowa Hospitals and Clinics Iowa 16D0664625 245064 | Not reported | Sequence analysis of the entire coding region\|Targeted variant analysis | Bi-directional Sanger Sequence Analysis\|PCR with allele specific hybridization | Cell culture\|Peripheral (whole) blood | Decline to answer | Yes
GTR000322431.2 | University of Iowa Diagnostic Laboratories University of Iowa Hospitals and Clinics Iowa 16D0664625 322431 | POMT1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Cell culture\|Peripheral (whole) blood | Decline to answer | Yes
GTR000325670.1 | University of Iowa Diagnostic Laboratories University of Iowa Hospitals and Clinics Iowa 16D0664625 325670 | FKTN | Sequence analysis of the entire coding region\|Targeted variant analysis | Bi-directional Sanger Sequence Analysis\|PCR with allele specific hybridization | Cell culture\|Peripheral (whole) blood | Decline to answer | Yes
GTR000330743.2 | University of Iowa Diagnostic Laboratories University of Iowa Hospitals and Clinics Iowa 16D0664625 330743 | LARGE | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Cell culture\|Peripheral (whole) blood | Decline to answer | Yes

Table D-6 Genetic tests for Prader-Willi syndrome

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000335345.1 | BayCare Cytogenetics Laboratory BayCare Laboratories, LLC Florida 10D2029560 335345 | SNRPN | FISH-metaphase | Digital/Virtual karyotyping | Peripheral (whole) blood | Decline to answer | Yes
GTR000512115.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512115 | 15q11-q13 | Targeted variant analysis | Trinucleotide repeat by PCR or Southern Blot | Not reported | Not reported | No
GTR000502862.1 | Center for Genetics at Saint Francis Saint Francis Hospital Oklahoma 37D0474681 502862 | SNRPN | Methylation analysis | Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000502968.1 | Center for Genetics at Saint Francis Saint Francis Hospital Oklahoma 37D0474681 502968 | SNRPN | Methylation analysis | Methylation-specific PCR | Cell culture\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000006792.2 | Center for Human Genetics Laboratory University Hospitals - University Hospitals Laboratory Service Foundation Ohio 36D0656024 6792 | SNRPN, 15q11.2, Chromsome 15 | FISH-metaphase\|Methylation analysis\|Uniparental disomy study (UPD) | Other\|Methylation-specific PCR\|Other | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000206885.1 | Center for Human Genetics, Inc Massachusetts 22D0650242 206885 | 15q11-q13 | FISH-metaphase\|Deletion/duplication analysis\|Methylation analysis\|Uniparental disomy study (UPD) | Fluorescence in situ Hybridization (FISH)\|Multiplex Ligation-dependent Probe Amplification (MLPA)\|Multiplex Ligation-dependent Probe Amplification (MLPA)\|PCR on ABI | Not reported | Decline to answer | No
GTR000196494.4 | ChildLab Molecular Genetics Laboratory Nationwide Children’s Hospital Ohio 36D0665271 196494 | SNRPN, 15q11.2-q13 | FISH-metaphase\|Methylation analysis\|Uniparental disomy study (UPD) | FISH\|Methylation-specific PCR\|characterization of microsatellite polymorphisms on an ABI instrument | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000295247.2 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 295247 | 15q11.2-q13 | FISH-metaphase | Metaphase FISH analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000509337.1 | Clinical Molecular Genetics Laboratory All Children’s Hospital Florida 10D0700790 509337 | 15q11-q13 | Methylation analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000327603.1 | Cytogenetics and Molecular Diagnostics Lab CGC Genetics USA New Jersey 31D1085261 327603 | Prader-Willi critical region | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis\|Methylation analysis | FISH\|FISH\|Multiplex Ligation-dependent Probe Amplification (MLPA)\|Methylation-specific PCR | Cell-free DNA\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000325591.1 | Cytogenetics and Molecular Genetics Laboratory Mercy St. Vincent Medical Center Ohio 36D0965797 325591 | 15q11.2 | FISH-metaphase\|Methylation analysis | FISH\|Methylation-specific PCR | Peripheral (whole) blood | Decline to answer | Yes
GTR000509082.1 | Cytogenetics and Molecular Pathology Laboratory DLP Marquette General Hospital, LLC Michigan 23D1062707 509082 | PWARSN | FISH-interphase\|FISH-metaphase\|Karyotyping | FISH\|FISH\|G-banding | Buccal swab\|Cord blood\|Fetal blood\|Peripheral (whole) blood | No | Yes
GTR000013522.1 | Cytogenetics Laboratory Indiana University School of Medicine Indiana 15D0647198 13522 | 15q11.2-q13 | FISH-interphase\|FISH-metaphase | Fluorescence in situ hybridization (FISH)\|Fluorescence in situ hybridization (FISH) | Amniocytes\|Amniotic fluid\|Bone marrow\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin\|Urine | Decline to answer | Yes
GTR000032599.1 | Cytogenetics Laboratory SUNY Upstate Medical University New York 33D0654590 32599 | 15q11.2 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Product of conception (POC)\|Skin | Yes | Yes
GTR000500042.2 | Cytogenetics Laboratory ARUP Laboratories, Inc. Utah 46D0523979 500042 | 15q11.2-q13\|17p11.2\|17p13.3\|22q11.2\|22q13.3\|4p16.3\|5p15.2\|7q11.23\|Xp22.3\|Yp11.3 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000503269.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503269 | SNRPN | Methylation analysis | Methylation-specific PCR | Not reported | No | No
GTR000503277.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 503277 | DMPK\|MEG3\|SMN1\|SNRPN | Methylation analysis\|Targeted variant analysis | Methylation-specific PCR\|Allele-specific PCR\|Trinucleotide repeat by PCR or Southern Blot | Not reported | No | No
GTR000512587.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512587 | ADSL\|AFF2\|AP1S2\|ARX\|ATRX\|BCKDK\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DHCR7\|DMD\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|HPRT1\|KDM5C\|L1CAM\|MAGEL2\|MBD5\|MECP2\|MED12\|MEF2C\|MID1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NR1I3\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RELN\|SCN1A\|SLC2A1\|SLC9A6\|SMARCB1\|SMC1A\|TCF4\|UBE2A\|UBE3A\|VPS13B\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000509342.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509342 | ANKRD11\|AP1S2\|ARX\|ATRX\|AUTS2\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CHD8\|CNTNAP2\|CNTNAP5\|CREBBP\|DHCR7\|DLGAP2\|DMD\|DOCK4\|DPP10\|DPP6\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GABRG1\|GNA14\|GRIN2B\|GRPR\|HOXA1\|HPRT1\|IMMP2L\|KATNAL2\|KCTD13\|KDM5C\|KIRREL3\|KLHL3\|L1CAM\|LAMC3\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|NEGR1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRXN1\|NSD1\|NTNG1\|OPHN1\|PAFAH1B1\|PCDH19\|PCDH9\|PDE10A\|PHF6\|PIP5K1B\|PNKP\|PON3\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RBFOX1\|RELN\|RPL10\|SATB2\|SCN1A\|SCN2A\|SHANK2\|SHANK3\|SLC6A4\|SLC9A6\|SLC9A9\|SMC1A\|SMG6\|SNRPN\|SOX5\|SPAST\|ST7\|STK3\|TCF4\|TSC1\|TSC2\|UBE3A\|VPS13B\|ZEB2\|ZNF507\|ZNF804A\|ZNHIT6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509392.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509392 | ABCC8\|ALMS1\|ARL6\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BDNF\|CEL\|CEP290\|EIF2AK3\|FOXP3\|GCK\|GLIS3\|GNAS\|HNF1A\|HNF1B\|HNF4A\|INS\|KCNJ11\|LEP\|LEPR\|MAGEL2\|MC4R\|MKKS\|MKS1\|NEUROD1\|NEUROG3\|NTRK2\|PCSK1\|PDX1\|POMC\|PTF1A\|RFX6\|SDCCAG8\|SIM1\|TRIM32\|TTC8\|WDPCP\|WFS1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000006812.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 6812 | 15q11.2-q13 | Methylation analysis | Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500159.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500159 | 15q11-q13 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000509731.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 509731 | MAGEL2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000274682.3 | Genetics Laboratory University of Oklahoma Health Sciences Center Oklahoma 37D0967945 274682 | SNRPN | Methylation analysis | Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000500313.1 | Genetics Laboratory Shodair Children’s Hospital Montana 27D0652530 500313 | SNRPN, 15q11.2-q13 | FISH-metaphase\|Methylation analysis\|Uniparental disomy study (UPD) | FISH\|Methylation-specific PCR\|Trinucleotide repeat by PCR or Southern Blot | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000004542.1 | Greenwood Genetic Center Diagnostic Laboratories Greenwood Genetic Center South Carolina 42D0689473 4542 | 15q11-q13 | Methylation analysis\|Uniparental disomy study (UPD) | Pyrosequencing\|Other | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Saliva\|Skin | Decline to answer | No
GTR000053126.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 53126 | 15q11.2-q13 | FISH-interphase\|FISH-metaphase\|Methylation analysis\|Uniparental disomy study (UPD) | Fluorescence in situ hybridization\|Fluorescence in situ hybridization\|Methylation-specific PCR\|Other | Fetal blood\|Peripheral (whole) blood | No | Yes
GTR000006562.2 | Knight Diagnostic Laboratories - Molecular Diagnostic Center Oregon Health and Science University Oregon 38D0881787 6562 | SNRPN | Deletion/duplication analysis\|Methylation analysis | MS-MLPA analysis of undigested and digested genomic DNA\|MS-MLPA analysis of undigested and digested genomic DNA | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000309920.1 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 309920 | SNRPN | Methylation analysis | Methylation-specific PCR | Not reported | Decline to answer | Yes
GTR000500630.2 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500630 | SNRPN | Methylation analysis | PCR with allele specific hybridization | Bone marrow\|Peripheral (whole) blood | No | Yes
GTR000500648.2 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500648 | 15q11.2 | FISH-metaphase | Other | Amniocytes\|Bone marrow\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | No | Yes
GTR000005898.3 | Molecular and Biochemical Genetics Laboratory Dayton Children’s Hospital Ohio 36D0859317 5898 | SNRPN | Methylation analysis | Methylation-specific PCR | Isolated DNA | Decline to answer | Yes
GTR000084935.1 | Molecular Diagnostic Laboratory Barnes Jewish Hospital Missouri 26D0438670 84935 | SNRPN | Methylation analysis | PCR-RFLP with Southern hybridization | Peripheral (whole) blood | Decline to answer | Yes
GTR000253215.1 | Molecular Diagnostics Laboratory Duke University Health System North Carolina 34D1005312 253215 | SNRPN | Methylation analysis | Methylation-specific PCR | Buccal swab\|Peripheral (whole) blood | Decline to answer | Yes
GTR000500322.1 | Molecular Diagnostics Laboratory University of California, San Francisco California 05D1024215 500322 | SNRPN | Methylation analysis | Other | Cell culture\|Peripheral (whole) blood | No | Yes
GTR000336252.1 | Molecular Genetics Diagnostic Laboratory Detroit Medical Center University Laboratories Michigan 23D0717194 336252 | SNRPN | Methylation analysis | Methylation-specific PCR | Peripheral (whole) blood | Decline to answer | Yes
GTR000166462.2 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 166462 | SNRPN | Methylation analysis | Methylation-specific PCR | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000193079.1 | Molecular Genetics Laboratory Children’s Mercy Hospital and Clinics Missouri 26D2046586 193079 | 15q11.2-q13 | Deletion/duplication analysis\|Methylation analysis | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Methylation-specific PCR | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000204881.2 | Molecular Genetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 204881 | SNRPN | Methylation analysis | Methylation-specific PCR | Not reported | Decline to answer | Yes
GTR000500706.2 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500706 | SNRPN | Methylation analysis | Methylation-specific PCR\|Other | Peripheral (whole) blood | Decline to answer | Yes
GTR000503131.2 | Natera California 05D1082992 503131 | 15q11-q13\|1p36\|22q11.2\|5p\|Chromosome 13\|Chromosome 18\|Chromosome 21\|Human genome\|Sex chromosome X | Targeted variant analysis | SNP Detection | Cell-free DNA\|Maternal blood sample | Decline to answer | No
GTR000500554.1 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 500554 | SNRPN | Methylation analysis | Methylation-specific PCR | Not reported | No | Yes
GTR000500555.1 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 500555 | SNRPN | Methylation analysis | Methylation-specific PCR | Not reported | No | Yes
GTR000504363.1 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 504363 | 15q11.2 | FISH-metaphase | Other | Peripheral (whole) blood | No | Yes
GTR000506046.2 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 506046 | 15q11.2-q13 | FISH-metaphase | Other | Amniocytes\|Chorionic villi\|Peripheral (whole) blood | No | Yes
GTR000501985.3 | Sequenom Center for Molecular Medicine - San Diego Sequenom CMM California 05D2015356 501985 | 1p36\|22q11.2\|5p15.2\|Chromosome 13\|Chromosome 15\|Chromosome 16\|Chromosome 18\|Chromosome 21\|Chromosome 22\|Sex chromosome X\|Sex chromosome Y | Targeted variant analysis | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000025316.1 | United States Air Force, DNA Diagnostic Laboratory United States Air Force Mississippi 25316 | Prader-Willi critical region | Methylation analysis | Methylation-specific PCR | Peripheral (whole) blood | Decline to answer | No
GTR000219915.1 | University of Iowa Diagnostic Laboratories University of Iowa Hospitals and Clinics Iowa 16D0664625 219915 | SNRPN, 15q11.2-q13 | Deletion/duplication analysis\|Methylation analysis | Southern blot hybridization\|Southern blot hybridization | Cell culture\|Peripheral (whole) blood | Decline to answer | Yes
GTR000305781.1 | UW Cytogenetic Services University of Wisconsin - Madison/WSLH Wisconsin 52D0669558 305781 | 15q11-q13 | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis\|Methylation analysis | Fluorescence In Situ Hybridization\|Fluorescence In Situ Hybridization\|Microarray\|Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Cord blood\|Peripheral (whole) blood | Decline to answer | Yes

Table D-7 Genetic tests for Rett syndrome

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000305902.5 | (AC) Atlanta Center: Medical Neurogenetics, LLC. NR Georgia 11D0703390 305902 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Buccal swab\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000319372.1 | Ambry Genetics Ambry Genetics California 05D0981414 319372 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000331025.2 | Ambry Genetics Ambry Genetics California 05D0981414 331025 | CDKL5\|MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Peripheral (whole) blood\|Saliva | No | Yes
GTR000500399.2 | Ambry Genetics Ambry Genetics California 05D0981414 500399 | FOXG1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000500401.2 | Ambry Genetics Ambry Genetics California 05D0981414 500401 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Cell culture\|Chorionic villi\|Isolated DNA\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000500402.2 | Ambry Genetics Ambry Genetics California 05D0981414 500402 | CDKL5\|FOXG1\|MECP2\|MEF2C | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Amniocytes\|Cell culture\|Chorionic villi\|Cord blood\|Isolated DNA\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000512790.2 | Athena Diagnostics Inc NR Massachusetts 22D0069726 512790 | ARHGEF9\|ARX\|ATP6AP2\|ATRX\|CASK\|CDKL5\|CUL4B\|DCX\|FGD1\|GPC3\|GRIA3\|HSD17B10\|KDM5C\|MECP2\|OFD1\|OPHN1\|PAK3\|PCDH19\|PHF6\|PLP1\|PQBP1\|RAB39B\|SLC9A6\|SMC1A\|SMS\|SRPX2\|SYP | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000512791.2 | Athena Diagnostics Inc NR Massachusetts 22D0069726 512791 | ARHGEF9\|ARX\|CDKL5\|CNTNAP2\|FOXG1\|GABRG2\|GRIN2A\|KCNT1\|MECP2\|NRXN1\|PCDH19\|PNKP\|RNASEH2A\|RNASEH2B\|RNASEH2C\|SAMHD1\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|STXBP1\|SYNGAP1\|TCF4\|TREX1\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000512792.2 | Athena Diagnostics Inc NR Massachusetts 22D0069726 512792 | ARX\|CDKL5\|FOXG1\|GABRB3\|GRIN2A\|MEF2C\|SCN2A\|SLC25A22\|SPTAN1\|STXBP1 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000512796.2 | Athena Diagnostics Inc NR Massachusetts 22D0069726 512796 | ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATRX\|CACNA1A\|CASK\|CASR\|CCDC88C\|CDKL5\|CHRNA2\|CHRNA4\|CHRNB2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COL18A1\|COL4A1\|CPT2\|CSTB\|CTSD\|CUL4B\|DCX\|DEPDC5\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FGD1\|FGFR3\|FKRP\|FKTN\|FLNA\|FOXG1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GPC3\|GPR56\|GRIA3\|GRIN2A\|HSD17B10\|KCNA1\|KCNJ1\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|LAMA2\|LARGE\|LBR\|LGI1\|MBD5\|ME2\|MECP2\|MEF2C\|MFSD8\|NHLRC1\|NIPBL\|NOTCH3\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PCDH19\|PEX7\|PHF6\|PIGV\|PLA2G6\|PLP1\|PNKP\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRRT2\|RAB39B\|RAB3GAP1\|RAI1\|RELN\|RNASEH2A\|RNASEH2B\|RNASEH2C\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SERPINI1\|SETBP1\|SLC25A22\|SLC2A1\|SLC4A10\|SLC9A6\|SMC1A\|SMC3\|SMS\|SNAP29\|SPTAN1\|SRPX2\|STXBP1\|SYNGAP1\|SYP\|TBC1D24\|TBX1\|TCF4\|TPP1\|TREX1\|TSC1\|TSC2\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VPS13A\|VPS13B\|WDR62\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000515153.1 | Athena Diagnostics Inc NR Massachusetts 22D0069726 515153 | FOXG1 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000515156.1 | Athena Diagnostics Inc NR Massachusetts 22D0069726 515156 | FOXG1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000515165.1 | Athena Diagnostics Inc NR Massachusetts 22D0069726 515165 | FOXG1 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | NR | No | Yes
GTR000515172.1 | Athena Diagnostics Inc NR Massachusetts 22D0069726 515172 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000515179.1 | Athena Diagnostics Inc NR Massachusetts 22D0069726 515179 | MECP2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000515187.1 | Athena Diagnostics Inc NR Massachusetts 22D0069726 515187 | MECP2 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | NR | No | Yes
GTR000508280.2 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 508280 | AARS2\|AASS\|ABAT\|ABCA12\|ABCA4\|ABCB11\|ABCB4\|ABCB6\|ABCB7\|ABCD1\|ABHD12\|ABHD5\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACO2\|ACOX1\|ACSF3\|ACSL4\|ADAM9\|ADCK3\|ADSL\|AFG3L2\|AGK\|AGL\|AGPS\|AGXT\|AIFM1\|AIPL1\|AK1\|AK2\|AKAP10\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|ALDOA\|ALDOB\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ALMS1\|AMACR\|AMER1\|AMN\|AMT\|ANKH\|ANKRD26\|AP3B1\|APP\|APTX\|ARG1\|ARL6\|ASL\|ASS1\|ATIC\|ATP5E\|ATP6V0A2\|ATP7A\|ATP7B\|ATP8B1\|ATPAF2\|AUH\|B4GALT1\|B4GALT7\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BCKDHA\|BCKDHB\|BCOR\|BCS1L\|BEST1\|BLOC1S3\|BOLA3\|BRCA1\|BTD\|C10orf2\|C12orf65\|C1QTNF5\|C2orf71\|C8orf37\|CA2\|CA4\|CABP4\|CACNA1F\|CACNA2D4\|CASP8\|CAT\|CBS\|CC2D2A\|CCDC28B\|CCDC39\|CDH23\|CDHR1\|CEP290\|CERKL\|CHAT\|CHM\|CISD2\|CLCN7\|CLN3\|CLRN1\|CNGA1\|CNGA3\|CNGB1\|CNGB3\|COG1\|COG7\|COG8\|COL1A1\|COL1A2\|COL2A1\|COL3A1\|COL5A1\|COL5A2\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|CPOX\|CPS1\|CPT1A\|CPT2\|CRB1\|CRTAP\|CRX\|CRYAB\|CTSA\|CTSD\|CTSK\|CUBN\|CYB5A\|CYB5R3\|CYBA\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP17A1\|CYP1B1\|CYP24A1\|CYP27A1\|CYP27B1\|CYP4V2\|D2HGDH\|DARS2\|DBT\|DDOST\|DFNB31\|DGUOK\|DHDDS\|DHODH\|DIABLO\|DLAT\|DLD\|DMGDH\|DNAJC19\|DNM1L\|DPM1\|DPM3\|DSP\|DTNBP1\|EFEMP1\|ELAC2\|ELN\|ELOVL4\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|EYA1\|EYA4\|EYS\|FAH\|FAM161A\|FAM20C\|FASTKD2\|FBLN5\|FBN1\|FBP1\|FECH\|FH\|FKBP10\|FLVCR1\|FOXC1\|FOXL2\|FOXRED1\|FRMD7\|FSCN2\|FXN\|FYCO1\|FZD4\|G6PC\|GAA\|GAD1\|GALC\|GALE\|GALK1\|GALNS\|GALT\|GAMT\|GARS\|GATM\|GBE1\|GCDH\|GCK\|GCKR\|GCSH\|GFER\|GFM1\|GIF\|GJA3\|GK\|GLB1\|GLDC\|GLRX5\|GLUD1\|GLYCTK\|GM2A\|GNAT1\|GNAT2\|GNE\|GNPTAB\|GNS\|GOT1\|GPD1\|GPD2\|GPI\|GPR143\|GPR98\|GPX1\|GRK1\|GRM6\|GRN\|GSN\|GUCA1A\|GUCA1B\|GUCY2D\|GUSB\|GYS1\|GYS2\|HADHA\|HADHB\|HAGH\|HARS\|HAX1\|HBB\|HCCS\|HESX1\|HEXA\|HEXB\|HGSNAT\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HNF1A\|HNF1B\|HP\|HPRT1\|HPS1\|HPS3\|HPS4\|HPS5\|HPS6\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH2\|IDH3B\|IMPDH1\|IMPG2\|INPP5E\|INVS\|IQCB1\|ISCU\|IVD\|JAG1\|KARS\|KCNJ13\|KCNV2\|KIF1B\|KIF21A\|KLHL7\|KRT12\|KRT3\|KRT5\|L2HGDH\|LCA5\|LDHA\|LDHB\|LEMD3\|LEPRE1\|LIAS\|LMBRD1\|LMX1B\|LPIN1\|LRAT\|LRP5\|LRPPRC\|MAN2B1\|MANBA\|MAOA\|MC1R\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MEF2A\|MEN1\|MERTK\|MFN2\|MFRP\|MGAT2\|MKKS\|MKS1\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MPDU1\|MPI\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MSRB3\|MTHFR\|MTO1\|MTPAP\|MTR\|MTRR\|MUT\|MUTYH\|MYO7A\|MYOC\|NAGLU\|NAGS\|NCOA4\|NDP\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NEFH\|NEUROD1\|NFU1\|NHS\|NME1\|NPHP1\|NPHP3\|NPHP4\|NRL\|NT5C3A\|NUBPL\|NYX\|OAT\|OCA2\|OCRL\|OGDH\|OGG1\|OPA1\|OPA3\|OPN1LW\|OPN1MW\|OPTN\|OSTM1\|OTC\|OTX2\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PAX2\|PAX6\|PC\|PCCA\|PCCB\|PCDH15\|PCK2\|PDE6A\|PDE6B\|PDE6C\|PDE6G\|PDHA1\|PDHB\|PDP1\|PDSS1\|PDSS2\|PDZD7\|PFKM\|PGAM2\|PGM1\|PHB\|PHKA1\|PHKA2\|PHKB\|PHKG2\|PHOX2A\|PHYH\|PINK1\|PITPNM3\|PITX2\|PITX3\|PLA2G2A\|PLOD2\|PLOD3\|PMM2\|PNKD\|PNPLA2\|POLG\|POLG2\|PPARG\|PPARGC1B\|PPIB\|PPOX\|PPP2R1B\|PRCD\|PRKCG\|PRODH\|PROM1\|PRPF31\|PRPF6\|PRPF8\|PRPH2\|PSAP\|PSEN1\|PTRF\|PTS\|PUS1\|PYCR1\|PYGL\|PYGM\|QDPR\|RAF1\|RARS2\|RAX\|RB1\|RD3\|RDH12\|RDH5\|REEP1\|RET\|RFT1\|RGR\|RGS9\|RHO\|RILP\|RIMS1\|RLBP1\|RNASEL\|RP1\|RP1L1\|RP2\|RP9\|RPE65\|RPGR\|RPGRIP1\|RPL35A\|RPS14\|RRM2B\|RS1\|SAG\|SARDH\|SARS2\|SCO2\|SCP2\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SECISBP2\|SEMA4A\|SEPT9\|SERPINF1\|SGSH\|SHH\|SIX6\|SLC16A1\|SLC22A4\|SLC22A5\|SLC24A1\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC26A4\|SLC34A1\|SLC35A1\|SLC35C1\|SLC37A4\|SLC39A13\|SLC3A1\|SLC45A2\|SLC9A3R1\|SLC9A6\|SMPD1\|SNCB\|SNRNP200\|SOD1\|SOD2\|SOST\|SOX2\|SP7\|SPATA7\|SPG7\|SPR\|SPTLC2\|SQSTM1\|SRD5A3\|STAR\|STAT1\|STAT3\|STRA6\|STXBP1\|SUCLA2\|SUCLG1\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TCN2\|TEAD1\|TGFB1\|TGFBI\|TIMM8A\|TIMP3\|TK2\|TLR3\|TLR4\|TMEM126A\|TMEM127\|TMEM67\|TMEM70\|TNFRSF11A\|TNFRSF11B\|TNFSF11\|TOPORS\|TP53\|TPP1\|TRIM32\|TRMU\|TRPM1\|TSFM\|TSPAN12\|TTC19\|TTC8\|TUBA1A\|TUBB3\|TUFM\|TULP1\|TUSC3\|TYMP\|TYR\|TYROBP\|TYRP1\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|USH1C\|USH1G\|USH2A\|VCP\|VHL\|VSX1\|WFS1\|WT1\|WWOX\|XDH\|XPNPEP3\|YARS2\|ZEB1\|ZFHX3\|ZNF513 | Deletion/duplication analysis | Comparative Genomic Hybridization | NR | NR | NR
GTR000511961.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511961 | FOXG1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000511962.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511962 | FOXG1 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000511963.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511963 | FOXG1 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512051.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512051 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512052.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512052 | MECP2 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | NR | NR | No
GTR000512053.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512053 | MECP2 | Deletion/duplication analysis | Trinucleotide repeat by PCR or Southern Blot | NR | NR | No
GTR000512054.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512054 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512055.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512055 | MECP2 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000512056.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512056 | MECP2 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | NR | NR | No
GTR000026276.1 | Center for Human Genetics, Inc NR Massachusetts 22D0650242 26276 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | NR | Decline to answer | No
GTR000298451.1 | Center for Human Genetics, Inc NR Massachusetts 22D0650242 298451 | Xq28 | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis | Fluorescence in situ Hybridization (FISH)\|Fluorescence in situ Hybridization (FISH)\|Multiplex Ligation-dependent Probe Amplification (MLPA) | NR | Decline to answer | No
GTR000322959.1 | Center for Human Genetics, Inc NR Massachusetts 22D0650242 322959 | FOXG1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | NR | Decline to answer | No
GTR000509362.2 | Clinical Molecular Genetics Laboratory All Children’s Hospital Florida 10D0700790 509362 | MECP2 | Mutation scanning of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Buccal swab\|Chorionic villi\|Fibroblasts\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | No
GTR000500883.8 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500883 | ABAT\|ABCC2\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|AKT3\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASAH1\|ASPA\|ASPM\|ATIC\|ATN1\|ATP1A2\|ATP1A3\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BRAF\|BRAT1\|BRD2\|BTD\|BUB1B\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT1A\|CPT2\|CSTB\|CTSA\|CTSD\|CTSF\|CUL4B\|CYP1B1\|CYP2A6\|CYP2B6\|CYP2C19\|CYP2C9\|CYP2D6\|CYP2R1\|CYP2U1\|CYP3A5\|DBT\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FAAH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FOXH1\|FUCA1\|GABBR2\|GABRA1\|GABRA2\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDH2\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIAS\|LIG4\|LRPPRC\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED12\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NGLY1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPA1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PIK3CA\|PIK3R2\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|RTTN\|SAMHD1\|SCARB2\|SCN10A\|SCN11A\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGCE\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SNIP1\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|ST3GAL5\|STIL\|STRADA\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TRPM6\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | No
GTR000500936.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500936 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|C21orf33\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|G6PD\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|HTT\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000503671.2 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 503671 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000510912.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 510912 | ADSL\|ALDH7A1\|ARHGEF9\|ARX\|ATP6AP2\|CACNB4\|CDKL5\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CSTB\|CTSD\|EFHC1\|EPM2A\|FOLR1\|FOXG1\|GABRA1\|GABRG2\|GAMT\|GATM\|GOSR2\|GRIN2A\|KANSL1\|KCNJ10\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|LGI1\|LIAS\|MAGI2\|MBD5\|MECP2\|MEF2C\|MFSD8\|NHLRC1\|NRXN1\|PCDH19\|PLCB1\|PNKP\|PNPO\|POLG\|PPT1\|PRICKLE1\|PRRT2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|STXBP1\|SYN1\|SYNGAP1\|TBC1D24\|TCF4\|TPP1\|TSC1\|TSC2\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fetal blood\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000501512.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501512 | FOXG1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | No | No
GTR000501513.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501513 | FOXG1 | Deletion/duplication analysis | Comparative Genomic Hybridization | NR | No | No
GTR000502819.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502819 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | No | No
GTR000502820.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502820 | MECP2 | Deletion/duplication analysis | Comparative Genomic Hybridization | NR | No | No
GTR000512416.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512416 | ABAT\|ADSL\|ALDH7A1\|ARHGEF9\|ARX\|ASPM\|ATP1A2\|ATP6AP2\|BCKDK\|CACNA1A\|CACNB4\|CASK\|CASR\|CDKL5\|CENPJ\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CPA6\|CSTB\|CTSD\|DCX\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FLNA\|FOLR1\|FOXG1\|GABRA1\|GABRG2\|GAMT\|GATM\|GOSR2\|GPR56\|GPR98\|GRIN2A\|HCN1\|HCN4\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|LGI1\|LIAS\|MAGI2\|MBD5\|MCPH1\|MECP2\|MEF2C\|MFSD8\|MTHFR\|NDE1\|NDUFA1\|NHLRC1\|NRXN1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PLCB1\|PNKP\|PNPO\|POLG\|PPT1\|PRICKLE1\|PRICKLE2\|PRRT2\|RELN\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN3A\|SCN8A\|SCN9A\|SHH\|SIX3\|SLC19A3\|SLC25A19\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|SRPX2\|ST3GAL3\|ST3GAL5\|STIL\|STXBP1\|SYN1\|TBC1D24\|TCF4\|TPP1\|TSC1\|TSC2\|TSEN54\|UBE3A\|WDR62\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512586.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512586 | ABCD1\|ACSL4\|AFF2\|AP1S2\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDK16\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|HCCS\|HCFC1\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|KLF8\|L1CAM\|LAMP2\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SYN1\|SYP\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|ZDHHC15\|ZDHHC9\|ZNF711 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512587.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512587 | ADSL\|AFF2\|AP1S2\|ARX\|ATRX\|BCKDK\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DHCR7\|DMD\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|HPRT1\|KDM5C\|L1CAM\|MAGEL2\|MBD5\|MECP2\|MED12\|MEF2C\|MID1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NR1I3\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RELN\|SCN1A\|SLC2A1\|SLC9A6\|SMARCB1\|SMC1A\|TCF4\|UBE2A\|UBE3A\|VPS13B\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512608.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512608 | ACTB\|ACTG1\|ADSL\|AHI1\|ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ASPM\|ATP1A2\|ATP6AP2\|ATR\|ATRX\|BCKDK\|CACNB4\|CASC5\|CASK\|CC2D2A\|CDC6\|CDK5RAP2\|CDKL5\|CDT1\|CENPJ\|CEP135\|CEP152\|CEP290\|CEP41\|CEP63\|CHMP1A\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CPA6\|CSTB\|CTSD\|DCX\|DHCR7\|DISP1\|DNAJC5\|EFHC1\|EHMT1\|EOMES\|EPM2A\|EXOSC3\|FGF8\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FOXH1\|GABRA1\|GABRG2\|GAMT\|GATM\|GLI2\|GOSR2\|GPR56\|GPR98\|GRIN2A\|GRIN2B\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KIAA1279\|KIF7\|LAMC3\|LARGE\|LARP7\|LGI1\|LIAS\|MAGI2\|MAPK10\|MBD5\|MCPH1\|MECP2\|MEF2C\|MFSD8\|MKS1\|MYCN\|NDE1\|NHLRC1\|NIN\|NODAL\|NPHP1\|NRXN1\|OPHN1\|ORC4\|ORC6\|PAFAH1B1\|PCDH19\|PCNT\|PLCB1\|PNKP\|PNPO\|POC1A\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRRT2\|PTCH1\|RAB18\|RAB3GAP1\|RAB3GAP2\|RARS2\|RBBP8\|RELN\|RPGRIP1L\|RTTN\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SHH\|SIX3\|SLC19A3\|SLC25A19\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|SRPX2\|ST3GAL3\|ST3GAL5\|STIL\|STXBP1\|SYN1\|TBC1D24\|TCF4\|TGIF1\|TMEM138\|TMEM216\|TMEM237\|TMEM67\|TPP1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|UBE3A\|VLDLR\|VRK1\|WDR62\|ZEB2\|ZIC2\|ZNF335 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000509342.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509342 | ANKRD11\|AP1S2\|ARX\|ATRX\|AUTS2\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CHD8\|CNTNAP2\|CNTNAP5\|CREBBP\|DHCR7\|DLGAP2\|DMD\|DOCK4\|DPP10\|DPP6\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GABRG1\|GNA14\|GRIN2B\|GRPR\|HOXA1\|HPRT1\|IMMP2L\|KATNAL2\|KCTD13\|KDM5C\|KIRREL3\|KLHL3\|L1CAM\|LAMC3\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|NEGR1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRXN1\|NSD1\|NTNG1\|OPHN1\|PAFAH1B1\|PCDH19\|PCDH9\|PDE10A\|PHF6\|PIP5K1B\|PNKP\|PON3\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RBFOX1\|RELN\|RPL10\|SATB2\|SCN1A\|SCN2A\|SHANK2\|SHANK3\|SLC6A4\|SLC9A6\|SLC9A9\|SMC1A\|SMG6\|SNRPN\|SOX5\|SPAST\|ST7\|STK3\|TCF4\|TSC1\|TSC2\|UBE3A\|VPS13B\|ZEB2\|ZNF507\|ZNF804A\|ZNHIT6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509399.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509399 | ABAT\|ABCB1\|ABCC8\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCS1L\|BRAF\|BTD\|BUB1B\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COG1\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|EFHC1\|EFHC2\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HCN1\|HCN4\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|IDS\|IDUA\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIG4\|LRPPRC\|MAGI2\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MLC1\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDSS1\|PDSS2\|PEX1\|PEX12\|PEX14\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PHF6\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN10A\|SCN1A\|SCN1B\|SCN2A\|SCN2B\|SCN3A\|SCN3B\|SCN4A\|SCN4B\|SCN5A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC17A5\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35C1\|SLC46A1\|SLC6A5\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRPX2\|STIL\|STXBP1\|SUMF1\|SUOX\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509430.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509430 | ACTB\|ACTG1\|ARX\|DCX\|FKRP\|FKTN\|LARGE\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|RELN\|TUBA1A\|VLDLR | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509432.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509432 | ACAD9\|ADCK3\|APTX\|ATP5E\|ATPAF2\|BCS1L\|COQ2\|COQ9\|COX10\|COX15\|COX6B1\|DARS2\|DGUOK\|DLAT\|DLD\|DNM1L\|ETFA\|ETFB\|ETFDH\|ETHE1\|FBP1\|FH\|FOXRED1\|G6PC\|GFM1\|GYS2\|ISCU\|LRPPRC\|MRPS16\|MRPS22\|NDUFA11\|NDUFAF1\|NDUFAF3\|NDUFAF4\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|PC\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|POLG\|PUS1\|RRM2B\|SCO2\|SLC25A3\|SLC25A4\|SUCLA2\|SUCLG1\|TAZ\|TK2\|TMEM70\|TRMU\|TSFM\|TUFM\|TYMP\|UQCRB\|YARS2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509436.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509436 | ABCC8\|ACY1\|ADAMTSL2\|ADSL\|AGA\|ALDH4A1\|ALDH5A1\|ALDH7A1\|AMT\|ANTXR2\|ARG1\|ARSA\|ARSB\|ASAH1\|ASPA\|ATP13A2\|BTD\|CLN3\|CLN5\|CLN6\|CLN8\|COL11A2\|COL2A1\|CTNS\|CTSA\|CTSC\|CTSD\|CTSK\|DHCR7\|DNAJC5\|DPYD\|DYM\|ETFA\|ETFB\|ETFDH\|FH\|FOLR1\|FUCA1\|GAA\|GALC\|GALNS\|GAMT\|GBA\|GCDH\|GCSH\|GLA\|GLB1\|GLDC\|GM2A\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GUSB\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|IDS\|IDUA\|L2HGDH\|LAMA2\|LAMP2\|LIPA\|LMBRD1\|MAN2B1\|MANBA\|MCOLN1\|MFSD8\|MOCS1\|MOCS2\|NAGA\|NAGLU\|NEU1\|NPC1\|NPC2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX26\|PEX3\|PEX5\|PEX6\|PGK1\|PHYH\|PPT1\|PRODH\|PSAP\|QDPR\|RAI1\|SGSH\|SLC17A5\|SLC25A15\|SLC46A1\|SMPD1\|SUMF1\|SUOX\|TCF4\|TPP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509442.11 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509442 | ABCC6\|ABCD1\|ABCG5\|ACAT1\|ACOX1\|ACSL4\|ACY1\|ADAR\|ADSL\|AFF2\|AFP\|AGL\|AGT\|AGTR2\|AHI1\|AIFM1\|ALDH18A1\|ALDH4A1\|ALG11\|ALG12\|ALG6\|ALX4\|AMER1\|AP1S1\|AP1S2\|AP3B1\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|APOB\|AQP7\|AR\|ARG1\|ARHGEF6\|ARID1A\|ARID1B\|ARX\|ASPM\|ASS1\|ATL1\|ATM\|ATP13A2\|ATP1A2\|ATP6AP2\|ATP7A\|ATRX\|AUH\|AVP\|AVPR2\|BBS9\|BCS1L\|BIN1\|BRCA2\|BRIP1\|BRWD3\|BUB1B\|CACNG2\|CAMTA1\|CANT1\|CASK\|CBS\|CC2D1A\|CC2D2A\|CCDC88C\|CDH15\|CDKL5\|CDKN1C\|CEP290\|CEP41\|CEP57\|CHD7\|CHRNA4\|CLN3\|CNTNAP2\|COG5\|COG7\|COL1A2\|CP\|CPA6\|CPS1\|CRADD\|CRBN\|CTC1\|CTNNB1\|CTSA\|CUL4B\|CYB5R3\|CYP27A1\|D2HGDH\|DARS2\|DBT\|DHCR24\|DHCR7\|DIP2B\|DLG3\|DMD\|DPYD\|DYNC1H1\|DYRK1A\|EBP\|EFNB1\|EHMT1\|ELOVL4\|ERCC2\|ERCC3\|ERCC5\|ERCC6\|ERCC8\|F5\|FAM126A\|FANCG\|FBLN5\|FBN1\|FBN2\|FGD1\|FGF14\|FGFR1\|FGFR2\|FGFR3\|FKRP\|FKTN\|FMR1\|FOXG1\|FOXP1\|FTO\|FTSJ1\|G6PC3\|GABRG2\|GALE\|GAMT\|GAN\|GBA\|GBE1\|GCK\|GDI1\|GFAP\|GFM1\|GHR\|GLI3\|GLRA1\|GLUL\|GLYCTK\|GM2A\|GNAS\|GNPAT\|GNPTAB\|GNPTG\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|GRM1\|GSS\|GUSB\|GYS2\|HAX1\|HDAC4\|HDAC8\|HEPACAM\|HEXB\|HOXD10\|HPD\|HSD17B10\|HSPD1\|HUWE1\|IDS\|IGBP1\|IGF1\|IGF1R\|IL1RAPL1\|INSR\|IQSEC2\|IRX5\|ITGA7\|KCNJ10\|KCNJ11\|KCNK9\|KCNQ2\|KCTD7\|KDM5C\|KIF11\|KIF1A\|KIF21A\|KIF5A\|KIF7\|KIRREL3\|KRAS\|L1CAM\|LAMA2\|LAMP2\|LARGE\|LBR\|LHX3\|LIG4\|LMBRD1\|LRP5\|LYST\|MAGT1\|MAN1B1\|MAN2B1\|MANBA\|MAPT\|MAT1A\|MBD5\|MBTPS2\|MCCC1\|MCCC2\|MCOLN1\|MCPH1\|MECP2\|MED17\|MED23\|MEF2C\|MFSD8\|MGAT2\|MKKS\|MMADHC\|MOCS2\|MPI\|MPZ\|MRAP\|MTFMT\|MTHFR\|MTR\|MYCN\|MYO5A\|MYO7A\|NAGA\|NBN\|NDP\|NDUFA1\|NDUFAF5\|NDUFS1\|NF1\|NGF\|NHEJ1\|NHP2\|NIPBL\|NLGN3\|NPC1\|NPC2\|NPHP3\|NRXN1\|NSDHL\|NSUN2\|OFD1\|OPHN1\|ORC1\|PAFAH1B1\|PAH\|PAK3\|PAX6\|PCDH19\|PCNT\|PDE4D\|PDHX\|PDSS1\|PEX7\|PGK1\|PHF8\|PHKA2\|PHKG2\|PIGL\|PIGO\|PIGV\|PLA2G6\|PLP1\|POMGNT1\|POMT1\|POMT2\|POU1F1\|PPOX\|PQBP1\|PRICKLE1\|PRKAR1A\|PRSS12\|PTEN\|PTPN11\|PYCR1\|PYGL\|RAB39B\|RAB40AL\|RAI1\|RAPSN\|RBBP8\|RBM10\|RFX6\|RPGRIP1L\|RPS6KA3\|SACS\|SAMHD1\|SATB2\|SCN1A\|SCN8A\|SDCCAG8\|SGCA\|SGSH\|SHANK2\|SHANK3\|SHROOM4\|SIL1\|SLC16A2\|SLC20A2\|SLC25A12\|SLC25A13\|SLC25A15\|SLC2A1\|SLC2A2\|SLC35C1\|SLC46A1\|SLC4A4\|SLC5A2\|SLC5A5\|SLC6A4\|SLC6A8\|SLC7A7\|SLC9A6\|SLX4\|SMARCA4\|SMARCB1\|SMC1A\|SMS\|SNIP1\|SOBP\|SOX10\|SOX2\|SOX3\|SPR\|SPTAN1\|SPTLC1\|SRD5A3\|SRPX2\|ST3GAL3\|STAT5B\|STRA6\|STX11\|STXBP1\|SUCLG1\|SYNGAP1\|SYP\|SYT14\|TBC1D24\|TBCE\|TBX1\|TECR\|TGIF1\|TH\|THRB\|TINF2\|TMCO1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPH2\|TPK1\|TRAPPC9\|TRHR\|TSC1\|TSC2\|TSHR\|TSPAN7\|TTC37\|TTR\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|TUSC3\|TWIST1\|UBE2A\|UBE3A\|UPB1\|UPF3B\|UROC1\|USP9X\|VLDLR\|VPS13B\|WDR62\|WDR81\|WRN\|XIST\|XPNPEP3\|ZBTB16\|ZBTB24\|ZDHHC9\|ZEB2\|ZFP57\|ZFYVE26\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | NR | NR
GTR000509443.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509443 | ALDH7A1\|ARX\|ATP1A2\|CACNA1A\|CDKL5\|FOLR1\|FOXG1\|GAMT\|KCNQ2\|MECP2\|PCDH19\|PHGDH\|PNPO\|POLG\|PPT1\|SCN1A\|SLC2A1\|STXBP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509444.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509444 | ACAD9\|ACADL\|ACADM\|ACADVL\|AGL\|C10orf2\|CPT1B\|CPT2\|GAA\|GYS1\|HADHA\|HADHB\|OPA1\|OPA3\|PFKM\|PGAM2\|PGM1\|PHKA1\|POLG\|POLG2\|RRM2B\|SUCLA2\|TK2\|TYMP | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509446.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509446 | C10orf2\|DGUOK\|MPV17\|POLG\|POLG2\|RRM2B\|SLC25A4\|SUCLA2\|SUCLG1\|TK2\|TYMP | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509453.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509453 | CLN3\|CLN5\|CLN6\|CLN8\|CTSD\|DNAJC5\|KCTD7\|MFSD8\|PPT1\|TPP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509462.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509462 | ARX\|ATRX\|CAV1\|CDKL5\|CNTNAP2\|FOXG1\|MECP2\|MED17\|MEF2C\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|TRAPPC9\|UBE3A\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510870.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510870 | DHFR\|FOLR1\|FPGS\|MTHFD1\|MTHFD1L\|MTHFS\|PTS\|SHMT1\|SLC19A1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510915.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510915 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ABCD3\|ACACA\|ACACB\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACLY\|ACO2\|ACSF3\|ACSL4\|ACSL5\|ACSM3\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AGXT2\|AIFM1\|AK2\|AKAP10\|AKR7A2\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|AS3MT\|ASS1\|ATIC\|ATP10D\|ATP5E\|ATP5SL\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BAX\|BCAT1\|BCAT2\|BCKDHA\|BCKDHB\|BCL2\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDC42BPB\|CDKL5\|CFTR\|CHAT\|CHDH\|CHRNA4\|CHRNB2\|CISD2\|CKM\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CLYBL\|CNR1\|COA5\|COMT\|COQ2\|COQ4\|COQ5\|COQ6\|COQ9\|COX10\|COX15\|COX4I1\|COX4I2\|COX6B1\|COX7A2\|CPOX\|CPS1\|CPT1A\|CPT1B\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDAH1\|DDC\|DECR1\|DGUOK\|DHODH\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNAJC5\|DNM1L\|DTNBP1\|EARS2\|ECI1\|ECSIT\|ELAC2\|ELN\|ENO1\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FAAH\|FARS2\|FASN\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FPGS\|FTH1\|FXN\|G6PC\|G6PD\|GAD1\|GAD2\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLO1\|GLRA1\|GLRX5\|GLS\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPAM\|GPD1\|GPD2\|GPI\|GPX1\|GPX4\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HARS\|HARS2\|HCCS\|HIBCH\|HIGD2A\|HK1\|HK2\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B1\|HSD3B2\|HSPA9\|HSPB7\|HSPD1\|HTRA2\|HTT\|IDE\|IDH1\|IDH2\|IDH3B\|IMMP2L\|IMMT\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|KYNU\|L2HGDH\|LARS2\|LDHA\|LDHB\|LETM1\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MAOB\|MARS2\|MAVS\|MCCC1\|MCCC2\|MCEE\|MDH1\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MGLL\|MGST3\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCOS\|MOCS1\|MOCS2\|MOGS\|MRPL3\|MRPL48\|MRPS16\|MRPS22\|MRRF\|MTCH2\|MTFMT\|MTHFD1\|MTHFD1L\|MTHFS\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA4\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB1\|NDUFB3\|NDUFB6\|NDUFB9\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NFU1\|NIPSNAP1\|NIPSNAP3A\|NLRX1\|NME1\|NOS3\|NPL\|NRXN1\|NTHL1\|NUBPL\|OAT\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PACRG\|PAH\|PAK7\|PANK2\|PARK2\|PARL\|PARP1\|PC\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PKLR\|PMPCA\|PNKD\|PNMT\|POLG\|POLG2\|POLRMT\|PPARGC1A\|PPARGC1B\|PPOX\|PPT1\|PREPL\|PRODH\|PTGES2\|PTS\|PUS1\|PYCR1\|QDPR\|RAB11FIP5\|RARS2\|REEP1\|RNASEL\|RPL35A\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SHMT1\|SIRT1\|SIRT3\|SIRT5\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A39\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|TACO1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TFAM\|TFB1M\|TIMM44\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOMM40\|TOP1MT\|TP53\|TPH2\|TPI1\|TPP1\|TRMU\|TSFM\|TSPO\|TST\|TTC19\|TUFM\|TXN2\|TXNRD2\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|USP24\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510916.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510916 | ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|AP1S2\|ARHGEF6\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|EBP\|FAAH2\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|GSPT2\|HCCS\|HDAC8\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|L1CAM\|LAMP2\|MAGT1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RAB40AL\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SRPX2\|SYN1\|SYP\|TAF1\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|USP9X\|WDR13\|ZCCHC12\|ZDHHC15\|ZDHHC9\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000055238.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 55238 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000298455.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 298455 | MECP2 | Deletion/duplication analysis | Methylation-specific PCR | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000319559.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 319559 | FOXG1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500160.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500160 | CDKL5\|FOXG1\|MECP2\|MEF2C | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500165.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500165 | FOXG1 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000501098.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 501098 | ARX\|ATRX\|CDKL5\|CNTNAP2\|DYRK1A\|EHMT1\|FOLR1\|FOXG1\|MBD5\|MECP2\|MEF2C\|NRXN1\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|UBE3A\|ZEB2 | Deletion/duplication analysis | Comparative Genomic Hybridization | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000501110.4 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 501110 | ARX\|ATRX\|CDKL5\|CNTNAP2\|DYRK1A\|EHMT1\|FOLR1\|FOXG1\|MBD5\|MECP2\|MEF2C\|NRXN1\|OPHN1\|PCDH19\|PNKP\|SLC2A1\|SLC9A6\|TCF4\|UBE3A\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000507771.3 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 507771 | ARFGEF2\|ASPM\|ATR\|ATRX\|CASC5\|CASK\|CDC6\|CDK5RAP2\|CDKL5\|CDT1\|CENPJ\|CEP135\|CEP152\|CEP63\|FOXG1\|MCPH1\|MECP2\|MED17\|NDE1\|ORC1\|ORC4\|ORC6\|PCNT\|PNKP\|RAB3GAP1\|RBBP8\|SLC25A19\|SLC2A1\|SLC9A6\|STAMBP\|STIL\|TCF4\|TSEN2\|TSEN34\|TSEN54\|UBE3A\|WDR62\|ZEB2\|ZNF335 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000321412.1 | Genetics Laboratory University of Oklahoma Health Sciences Center Oklahoma 37D0967945 321412 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000030362.1 | Greenwood Genetic Center Diagnostic Laboratories Greenwood Genetic Center South Carolina 42D0689473 30362 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Saliva\|Skin | Decline to answer | Yes
GTR000314263.1 | Greenwood Genetic Center Diagnostic Laboratories Greenwood Genetic Center South Carolina 42D0689473 314263 | FOXG1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Isolated DNA\|Peripheral (whole) blood\|Saliva\|Skin | Decline to answer | Yes
GTR000327662.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 327662 | AP1S2\|ARX\|ASPM\|ATRX\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CBL\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DCX\|DHCR7\|DMD\|EHMT1\|ERCC6\|ERCC8\|FGD1\|FGFR1\|FGFR2\|FGFR3\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|HDAC8\|HOXA1\|HPRT1\|HRAS\|KDM5C\|KMT2D\|KRAS\|L1CAM\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|MKKS\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCH1\|PTEN\|PTPN11\|RAB39B\|RAD21\|RAF1\|RAI1\|RELN\|RPGRIP1L\|RPS6KA3\|SCN1A\|SHANK2\|SHANK3\|SHOC2\|SLC2A1\|SLC6A4\|SLC9A6\|SMC1A\|SMC3\|SOS1\|SPRED1\|TCF4\|TSC1\|TSC2\|TUBA1A\|UBE3A\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | No | No
GTR000004996.2 | Knight Diagnostic Laboratories - Molecular Diagnostic Center Oregon Health and Science University Oregon 38D0881787 4996 | MECP2 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000232787.2 | Knight Diagnostic Laboratories - Molecular Diagnostic Center Oregon Health and Science University Oregon 38D0881787 232787 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000331373.2 | Knight Diagnostic Laboratories - Molecular Diagnostic Center Oregon Health and Science University Oregon 38D0881787 331373 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Fetal blood\|Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000205558.4 | Molecular Diagnostics Lab Nemours Alfred I. duPont Hospital for Children Delaware 08D0706140 205558 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Quantitative multiplex PCR to determine copy number\|Bi-directional Sanger Sequence Analysis | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000328852.3 | Molecular Diagnostics Lab Nemours Alfred I. duPont Hospital for Children Delaware 08D0706140 328852 | MECP2 | Deletion/duplication analysis | Quantitative multiplex PCR to determine exon copy number | Isolated DNA\|Peripheral (whole) blood | Decline to answer | Yes
GTR000322184.2 | Molecular Genetics Diagnostic Laboratory Detroit Medical Center University Laboratories Michigan 23D0717194 322184 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000245100.1 | Molecular Genetics Laboratory Children’s Mercy Hospital and Clinics Missouri 26D2046586 245100 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000298463.1 | Molecular Genetics Laboratory Children’s Mercy Hospital and Clinics Missouri 26D2046586 298463 | MECP2 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Isolated DNA\|Peripheral (whole) blood | Decline to answer | No
GTR000500546.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500546 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000500583.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500583 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | Yes
GTR000500584.1 | Molecular Genetics Laboratory ARUP Laboratories Utah 46D0523979 500584 | MECP2 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Amniocytes\|Amniotic fluid\|Peripheral (whole) blood | Decline to answer | Yes
GTR000501476.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501476 | FOXG1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501477.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501477 | FOXG1 | Sequence analysis of the entire coding region | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501478.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501478 | FOXG1 | Targeted variant analysis | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501479.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501479 | FOXG1 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501562.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501562 | ARX\|CDKL5\|MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501700.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501700 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501701.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501701 | MECP2 | Sequence analysis of the entire coding region | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501702.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501702 | MECP2 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000501703.1 | Molecular Genetics Laboratory Children’s Hospital of Philadelphia Pennsylvania 39D0198678 501703 | MECP2 | Targeted variant analysis | Uni-directional Sanger sequencing | Bone marrow\|Buccal swab\|Cell culture\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Paraffin block\|Peripheral (whole) blood | No | Yes
GTR000507942.2 | Pittsburgh Cytogenetics Laboratory University of Pittsburgh Medical Center Pennsylvania 39D0673863 507942 | ABCB7\|ABCD1\|ACSL4\|AFF2\|AGTR2\|AIFM1\|ALAS2\|ALG13\|AMELX\|AMER1\|AP1S2\|AR\|ARHGEF6\|ARHGEF9\|ARSE\|ARX\|ATP2B3\|ATP6AP2\|ATP7A\|ATRX\|AVPR2\|BCOR\|BRWD3\|BTK\|CACNA1F\|CASK\|CDKL5\|CFP\|CHM\|CHRDL1\|CLCN5\|CLIC2\|COL4A5\|COX7B\|CSF2RA\|CYBB\|DCX\|DKC1\|DLG3\|DMD\|EBP\|EDA\|EFNB1\|EMD\|F8\|F9\|FAM58A\|FANCB\|FHL1\|FLNA\|FTSJ1\|G6PD\|GATA1\|GDI1\|GJB1\|GK\|GLA\|GPR143\|GRIA3\|HCCS\|HCFC1\|HDAC8\|HPRT1\|HSD17B10\|IDS\|IGBP1\|IGSF1\|IKBKG\|IL1RAPL1\|IL2RG\|KAL1\|KDM5C\|KDM6A\|L1CAM\|LAMP2\|MAGT1\|MAMLD1\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|MTM1\|NAA10\|NDP\|NHS\|NLGN3\|NLGN4X\|NR0B1\|NSDHL\|OCRL\|OFD1\|OPHN1\|OPN1MW\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PHKA1\|PHKA2\|PIGA\|PLP1\|POLA1\|PORCN\|POU3F4\|PQBP1\|PRPS1\|RAB39B\|RAB40AL\|RBM10\|RP2\|RPGR\|RPL10\|RPS6KA3\|RS1\|SAT1\|SERPINA7\|SH2D1A\|SHOX\|SHROOM4\|SLC16A2\|SLC35A2\|SLC6A14\|SLC6A8\|SLC9A6\|SMPX\|SMS\|SOX3\|SRPX2\|SRY\|STS\|SYN1\|SYP\|TAF1\|TAZ\|TBX22\|TIMM8A\|TMLHE\|TRAPPC2\|TSPAN7\|UBA1\|UBE2A\|UBQLN2\|UPF3B\|VMA21\|WAS\|WDR45\|XIAP\|XK\|ZC4H2\|ZDHHC15\|ZDHHC9\|ZIC3\|ZNF41\|ZNF674\|ZNF711\|ZNF81 | Deletion/duplication analysis | Comparative Genomic Hybridization | Amniotic fluid\|Cell culture\|Chorionic villi\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | No
GTR000508539.3 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 508539 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000509896.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 509896 | ARHGEF9\|ARX\|CDKL5\|CHD2\|EFHC1\|GABRA1\|GABRB3\|GABRG2\|GRIN2A\|MBD5\|MECP2\|MEF2C\|PCDH19\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SLC2A1\|SLC9A6\|SPTAN1\|STXBP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region\|Targeted variant analysis | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000511097.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 511097 | FOXG1 | Sequence analysis of the entire coding region\|Targeted variant analysis | Bi-directional Sanger Sequence Analysis\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000508076.1 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 508076 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | No | Yes
GTR000508077.1 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 508077 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | No | Yes
GTR000508078.1 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 508078 | MECP2 | Deletion/duplication analysis | Other | NR | No | Yes
GTR000336125.2 | Transgenomic Transgenomic Connecticut 07D0995237 336125 | MECP2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA)\|Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood\|Saliva | Decline to answer | Yes
GTR000501919.2 | Transgenomic Transgenomic Connecticut 07D0995237 501919 | AARS2\|AASS\|ABAT\|ABCB7\|ABCD1\|ABHD5\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADSB\|ACADVL\|ACAT1\|ACSF3\|ACSL4\|ADCK3\|AFG3L2\|AGXT\|AIFM1\|AIFM2\|AK2\|AKR1D1\|ALAS2\|ALDH18A1\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMACR\|AMT\|APEX2\|APTX\|ARG1\|ARMS2\|ASL\|ASS1\|ATL1\|ATM\|ATP5A1\|ATP5B\|ATP5C1\|ATP5D\|ATP5E\|ATP5F1\|ATP5G1\|ATP5G2\|ATP5G3\|ATP5I\|ATP5J\|ATP5O\|ATP7B\|ATPAF1\|ATPAF2\|ATPIF1\|ATXN10\|ATXN7\|AUH\|B4GALT1\|BCKDHA\|BCKDHB\|BCS1L\|BRAF\|BTD\|C10orf2\|C12orf65\|C14orf2\|CAPN3\|CARS2\|CAV3\|CDKL5\|CHKB\|CISD2\|CLN3\|CLN5\|CLN6\|CLN8\|CMC1\|COG1\|COG7\|COG8\|COQ2\|COQ3\|COQ4\|COQ6\|COQ7\|COQ9\|COX10\|COX11\|COX15\|COX17\|COX18\|COX19\|COX4I1\|COX4I2\|COX5A\|COX5B\|COX6A1\|COX6A2\|COX6B1\|COX6C\|COX7A1\|COX7A2\|COX7A2L\|COX7B\|COX7B2\|COX7C\|COX8A\|CPOX\|CPS1\|CPT1A\|CPT2\|CRLS1\|CRYAB\|CTNS\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYC1\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP27A1\|CYP27B1\|CYP7B1\|D2HGDH\|DARS2\|DBT\|DCX\|DECR1\|DGUOK\|DLAT\|DLD\|DLST\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DNM2\|DOLK\|DPAGT1\|DPM1\|DPM3\|EARS2\|ECSIT\|EIF2AK3\|ELOVL4\|ETFA\|ETFB\|ETFDH\|ETHE1\|FA2H\|FARS2\|FASTKD2\|FECH\|FGF14\|FH\|FOXG1\|FOXRED1\|FXN\|GAA\|GAD1\|GAMT\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLA\|GLDC\|GLRX5\|GLUD1\|GNPAT\|GPD2\|GPHN\|HADH\|HADHA\|HADHB\|HARS2\|HAX1\|HCCS\|HFE\|HK1\|HLCS\|HMGCL\|HMGCS2\|HSD17B10\|HSD3B2\|HSPD1\|IARS2\|IDH2\|ISCU\|ITPR1\|IVD\|KARS\|KCNC3\|KCNJ11\|KIAA0196\|KIAA0226\|KIF1B\|KIF5A\|LARS2\|LETM1\|LMBRD1\|LRPPRC\|MAOA\|MAPT\|MARS2\|MCCC1\|MCCC2\|ME2\|MECP2\|MFN2\|MFSD8\|MGAT2\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MPV17\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|MYH7\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA3\|NDUFA4\|NDUFA5\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAB1\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB1\|NDUFB10\|NDUFB11\|NDUFB2\|NDUFB3\|NDUFB4\|NDUFB5\|NDUFB6\|NDUFB7\|NDUFB8\|NDUFB9\|NDUFC1\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NEFL\|NIPA1\|NKX2-1\|NPC1\|NPC2\|NUBPL\|OAT\|OGDH\|OPA1\|OPA3\|OTC\|OXA1L\|OXCT1\|PAFAH1B1\|PANK2\|PARL\|PARS2\|PC\|PCCA\|PCCB\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX13\|PHB\|PHYH\|PLP1\|PMM2\|PNKD\|PNPLA2\|PNPLA3\|POLG\|POLG2\|PPM1B\|PPOX\|PPT1\|PREPL\|PRKCG\|PRODH\|PUS1\|PWAR1\|RARS2\|REEP1\|RFT1\|RMRP\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RRM2B\|RYR1\|SAMHD1\|SARS2\|SCN1A\|SCO1\|SCO2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SGCD\|SLC12A3\|SLC16A2\|SLC19A2\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A16\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC29A3\|SLC2A1\|SLC2A10\|SLC33A1\|SLC35A1\|SLC35C1\|SLC3A1\|SLC52A1\|SLC6A8\|SLC7A9\|SOD1\|SPAST\|SPG11\|SPG20\|SPG7\|SPTBN2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TACO1\|TARS2\|TAZ\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOP1MT\|TPM2\|TPP1\|TRMU\|TSFM\|TTBK2\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCR10\|UQCR11\|UQCRB\|UQCRC1\|UQCRC2\|UQCRFS1\|UQCRH\|UQCRQ\|UROS\|USMG5\|VARS2\|WARS2\|WFS1\|XDH\|XPNPEP3\|YARS2\|ZFYVE26 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000509336.2 | Transgenomic Transgenomic Connecticut 07D0995237 509336 | ABAT\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDK\|BCS1L\|BRAF\|BTD\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCDC88C\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX10\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EOMES\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LRPPRC\|MAGI2\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFAF6\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHLRC1\|NIPBL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RBFOX1\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC4A10\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|STIL\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VDAC1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000205580.1 | United States Air Force, DNA Diagnostic Laboratory United States Air Force Mississippi NR 205580 | MECP2 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Peripheral (whole) blood | Decline to answer | No

NR: Not reported

Table D-8 Genetic tests for Rubinstein-Taybi syndrome

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000511929.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511929 | CREBBP | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Multiplex Ligation-dependent Probe Amplification (MLPA\|Bi-directional Sanger Sequence Analysis | — | — | No
GTR000511930.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511930 | CREBBP | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | — | — | No
GTR000511931.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511931 | CREBBP | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | — | — | No
GTR000511932.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511932 | CREBBP | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | — | — | No
GTR000511933.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511933 | CREBBP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | — | — | No
GTR000511934.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 511934 | CREBBP | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | — | — | No
GTR000320329.1 | Center for Human Genetics Laboratory University Hospitals - University Hospitals Laboratory Service Foundation Ohio 36D0656024 320329 | 16p13.3 | FISH-metaphase | Other | Amniocytes\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000502732.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502732 | CREBBP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | — | No | No
GTR000502734.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502734 | CREBBP | Deletion/duplication analysis | Comparative Genomic Hybridization | — | No | No
GTR000502735.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502735 | EP300 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | — | No | No
GTR000512423.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512423 | ATRX\|BLM\|BTK\|CREBBP\|CUL7\|DHCR7\|EP300\|ERCC6\|ERCC8\|FGD1\|GH1\|GHR\|GHRHR\|GLI2\|HESX1\|IGF1\|IGF1R\|INSR\|KDM6A\|KMT2D\|KRAS\|LHX3\|NBN\|NIPBL\|PITX2\|POU1F1\|PROP1\|PTPN11\|RAF1\|ROR2\|RPS6KA3\|SHOX\|SHOX2\|SMARCAL1\|SMC1A\|SMC3\|SOS1\|SOX2\|SOX3\|SRCAP\|STAT5B\|TBCE\|THRB\|TRIM37\|WRN | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | — | No | No
GTR000512587.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512587 | ADSL\|AFF2\|AP1S2\|ARX\|ATRX\|BCKDK\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DHCR7\|DMD\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|HPRT1\|KDM5C\|L1CAM\|MAGEL2\|MBD5\|MECP2\|MED12\|MEF2C\|MID1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NR1I3\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RELN\|SCN1A\|SLC2A1\|SLC9A6\|SMARCB1\|SMC1A\|TCF4\|UBE2A\|UBE3A\|VPS13B\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | — | No | No
GTR000509342.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509342 | ANKRD11\|AP1S2\|ARX\|ATRX\|AUTS2\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CHD8\|CNTNAP2\|CNTNAP5\|CREBBP\|DHCR7\|DLGAP2\|DMD\|DOCK4\|DPP10\|DPP6\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GABRG1\|GNA14\|GRIN2B\|GRPR\|HOXA1\|HPRT1\|IMMP2L\|KATNAL2\|KCTD13\|KDM5C\|KIRREL3\|KLHL3\|L1CAM\|LAMC3\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|NEGR1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRXN1\|NSD1\|NTNG1\|OPHN1\|PAFAH1B1\|PCDH19\|PCDH9\|PDE10A\|PHF6\|PIP5K1B\|PNKP\|PON3\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RBFOX1\|RELN\|RPL10\|SATB2\|SCN1A\|SCN2A\|SHANK2\|SHANK3\|SLC6A4\|SLC9A6\|SLC9A9\|SMC1A\|SMG6\|SNRPN\|SOX5\|SPAST\|ST7\|STK3\|TCF4\|TSC1\|TSC2\|UBE3A\|VPS13B\|ZEB2\|ZNF507\|ZNF804A\|ZNHIT6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510913.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510913 | CREBBP\|DHCR7\|EP300\|FGD1\|KRAS\|NIPBL\|PTPN11\|RAF1\|SMC1A\|SOS1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000320336.2 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 320336 | CREBBP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000330884.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 330884 | EP300 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500145.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500145 | CREBBP | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000500163.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 500163 | EP300 | Deletion/duplication analysis | Multiplex Ligation-dependent Probe Amplification (MLPA) | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva | Decline to answer | Yes
GTR000327662.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 327662 | AP1S2\|ARX\|ASPM\|ATRX\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CBL\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DCX\|DHCR7\|DMD\|EHMT1\|ERCC6\|ERCC8\|FGD1\|FGFR1\|FGFR2\|FGFR3\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|HDAC8\|HOXA1\|HPRT1\|HRAS\|KDM5C\|KMT2D\|KRAS\|L1CAM\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|MKKS\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCH1\|PTEN\|PTPN11\|RAB39B\|RAD21\|RAF1\|RAI1\|RELN\|RPGRIP1L\|RPS6KA3\|SCN1A\|SHANK2\|SHANK3\|SHOC2\|SLC2A1\|SLC6A4\|SLC9A6\|SMC1A\|SMC3\|SOS1\|SPRED1\|TCF4\|TSC1\|TSC2\|TUBA1A\|UBE3A\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | No | No
GTR000503218.3 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503218 | CREBBP | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000503219.2 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503219 | CREBBP | Deletion/duplication analysis | Microarray | — | Decline to answer | No
GTR000503220.3 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503220 | EP300 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Buccal swab\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\| Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000503221.2 | Molecular Genetics Laboratory Children’s Hospital Colorado Colorado 06D0644348 503221 | EP300 | Deletion/duplication analysis | Microarray | — | Decline to answer | No

Table D-9 Genetic tests for Smith-Magenis syndrome

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000512797.2 | Athena Diagnostics Inc Massachusetts 22D0069726 512797 | ATP2A2\|ATP6V0A2\|CCDC88C\|CLCNKA\|CLCNKB\|KCNA1\|KCNJ1\|KCNJ10\|KIAA1279\|KMT2D\|LBR\|LGI1\|NIPBL\|PANK2\|PIGV\|PLA2G6\|RAI1\|SERPINI1\|SETBP1\|SMC3\|SYNGAP1\|TBX1\|TSC1\|TSC2\|VPS13A\|VPS13B | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000512796.2 | Athena Diagnostics Inc Massachusetts 22D0069726 512796 | ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATRX\|CACNA1A\|CASK\|CASR\|CCDC88C\|CDKL5\|CHRNA2\|CHRNA4\|CHRNB2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COL18A1\|COL4A1\|CPT2\|CSTB\|CTSD\|CUL4B\|DCX\|DEPDC5\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FGD1\|FGFR3\|FKRP\|FKTN\|FLNA\|FOXG1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GPC3\|GPR56\|GRIA3\|GRIN2A\|HSD17B10\|KCNA1\|KCNJ1\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|LAMA2\|LARGE\|LBR\|LGI1\|MBD5\|ME2\|MECP2\|MEF2C\|MFSD8\|NHLRC1\|NIPBL\|NOTCH3\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PCDH19\|PEX7\|PHF6\|PIGV\|PLA2G6\|PLP1\|PNKP\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRRT2\|RAB39B\|RAB3GAP1\|RAI1\|RELN\|RNASEH2A\|RNASEH2B\|RNASEH2C\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SERPINI1\|SETBP1\|SLC25A22\|SLC2A1\|SLC4A10\|SLC9A6\|SMC1A\|SMC3\|SMS\|SNAP29\|SPTAN1\|SRPX2\|STXBP1\|SYNGAP1\|SYP\|TBC1D24\|TBX1\|TCF4\|TPP1\|TREX1\|TSC1\|TSC2\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VPS13A\|VPS13B\|WDR62\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | Yes
GTR000512125.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512125 | RAI1 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512124.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512124 | RAI1 | Targeted variant analysis | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000512123.1 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 512123 | RAI1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | Not reported | No
GTR000019599.1 | Center for Human Genetics Laboratory University Hospitals - University Hospitals Laboratory Service Foundation Ohio 36D0656024 19599 | 17p11.2 | FISH-metaphase | Other | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fetal blood\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000206875.1 | Center for Human Genetics, Inc Massachusetts 22D0650242 206875 | 17p11.2 | FISH-metaphase | Fluorescence in situ Hybridization (FISH) | Not reported | Decline to answer | No
GTR000295249.1 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 295249 | 17p11.2 | FISH-metaphase | Metaphase FISH analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000500883.8 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500883 | ABAT\|ABCC2\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|AKT3\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASAH1\|ASPA\|ASPM\|ATIC\|ATN1\|ATP1A2\|ATP1A3\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BRAF\|BRAT1\|BRD2\|BTD\|BUB1B\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT1A\|CPT2\|CSTB\|CTSA\|CTSD\|CTSF\|CUL4B\|CYP1B1\|CYP2A6\|CYP2B6\|CYP2C19\|CYP2C9\|CYP2D6\|CYP2R1\|CYP2U1\|CYP3A5\|DBT\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FAAH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FOXH1\|FUCA1\|GABBR2\|GABRA1\|GABRA2\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDH2\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIAS\|LIG4\|LRPPRC\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED12\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NGLY1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPA1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PIK3CA\|PIK3R2\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|RTTN\|SAMHD1\|SCARB2\|SCN10A\|SCN11A\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGCE\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SNIP1\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|ST3GAL5\|STIL\|STRADA\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TRPM6\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | No
GTR000325583.1 | Cytogenetics and Molecular Genetics Laboratory Mercy St. Vincent Medical Center Ohio 36D0965797 325583 | 17p11.2 | FISH-metaphase | FISH | Peripheral (whole) blood | Decline to answer | Yes
GTR000509083.1 | Cytogenetics and Molecular Pathology Laboratory DLP Marquette General Hospital, LLC Michigan 23D1062707 509083 | RAI1 | FISH-interphase\|FISH-metaphase\|Karyotyping | FISH\|FISH\|G-banding | Buccal swab\|Cord blood\|Fetal blood\|Peripheral (whole) blood | No | Yes
GTR000500042.2 | Cytogenetics Laboratory ARUP Laboratories, Inc. Utah 46D0523979 500042 | 15q11.2-q13\|17p11.2\|17p13.3\|22q11.2\|22q13.3\|4p16.3\|5p15.2\|7q11.23\|Xp22.3\|Yp11.3 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000013536.1 | Cytogenetics Laboratory Indiana University School of Medicine Indiana 15D0647198 13536 | 17p11.2 | FISH-interphase\|FISH-metaphase | Fluorescence in situ hybridization (FISH)\|Fluorescence in situ hybridization (FISH) | Amniocytes\|Amniotic fluid\|Bone marrow\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin\|Urine | Decline to answer | Yes
GTR000512587.2 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512587 | ADSL\|AFF2\|AP1S2\|ARX\|ATRX\|BCKDK\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DHCR7\|DMD\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|HPRT1\|KDM5C\|L1CAM\|MAGEL2\|MBD5\|MECP2\|MED12\|MEF2C\|MID1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NR1I3\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RELN\|SCN1A\|SLC2A1\|SLC9A6\|SMARCB1\|SMC1A\|TCF4\|UBE2A\|UBE3A\|VPS13B\|ZEB2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000512586.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512586 | ABCD1\|ACSL4\|AFF2\|AP1S2\|ARHGEF9\|ARX\|ATP6AP2\|ATP7A\|ATRX\|BCOR\|BRWD3\|CASK\|CCDC22\|CDK16\|CDKL5\|CLIC2\|CNKSR2\|CUL4B\|DCX\|DKC1\|DLG3\|DMD\|FANCB\|FGD1\|FLNA\|FMR1\|FRMPD4\|FTSJ1\|GDI1\|GK\|GPC3\|GRIA3\|HCCS\|HCFC1\|HPRT1\|HSD17B10\|HUWE1\|IDS\|IGBP1\|IL1RAPL1\|IQSEC2\|KDM5C\|KIAA2022\|KLF8\|L1CAM\|LAMP2\|MAOA\|MBTPS2\|MECP2\|MED12\|MID1\|NAA10\|NDP\|NDUFA1\|NHS\|NLGN3\|NLGN4X\|NSDHL\|OCRL\|OFD1\|OPHN1\|OTC\|PAK3\|PCDH19\|PDHA1\|PGK1\|PHF6\|PHF8\|PLP1\|PORCN\|PQBP1\|PRPS1\|PTCHD1\|RAB39B\|RBM10\|RPL10\|RPS6KA3\|SHROOM4\|SLC16A2\|SLC9A6\|SMC1A\|SMS\|SOX3\|SYN1\|SYP\|TIMM8A\|TSPAN7\|UBE2A\|UPF3B\|ZDHHC15\|ZDHHC9\|ZNF711 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Microarray\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | No | No
GTR000502986.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502986 | RAI1 | Deletion/duplication analysis | Comparative Genomic Hybridization | Not reported | No | No
GTR000502985.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 502985 | RAI1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Not reported | No | No
GTR000509442.11 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509442 | ABCC6\|ABCD1\|ABCG5\|ACAT1\|ACOX1\|ACSL4\|ACY1\|ADAR\|ADSL\|AFF2\|AFP\|AGL\|AGT\|AGTR2\|AHI1\|AIFM1\|ALDH18A1\|ALDH4A1\|ALG11\|ALG12\|ALG6\|ALX4\|AMER1\|AP1S1\|AP1S2\|AP3B1\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|APOB\|AQP7\|AR\|ARG1\|ARHGEF6\|ARID1A\|ARID1B\|ARX\|ASPM\|ASS1\|ATL1\|ATM\|ATP13A2\|ATP1A2\|ATP6AP2\|ATP7A\|ATRX\|AUH\|AVP\|AVPR2\|BBS9\|BCS1L\|BIN1\|BRCA2\|BRIP1\|BRWD3\|BUB1B\|CACNG2\|CAMTA1\|CANT1\|CASK\|CBS\|CC2D1A\|CC2D2A\|CCDC88C\|CDH15\|CDKL5\|CDKN1C\|CEP290\|CEP41\|CEP57\|CHD7\|CHRNA4\|CLN3\|CNTNAP2\|COG5\|COG7\|COL1A2\|CP\|CPA6\|CPS1\|CRADD\|CRBN\|CTC1\|CTNNB1\|CTSA\|CUL4B\|CYB5R3\|CYP27A1\|D2HGDH\|DARS2\|DBT\|DHCR24\|DHCR7\|DIP2B\|DLG3\|DMD\|DPYD\|DYNC1H1\|DYRK1A\|EBP\|EFNB1\|EHMT1\|ELOVL4\|ERCC2\|ERCC3\|ERCC5\|ERCC6\|ERCC8\|F5\|FAM126A\|FANCG\|FBLN5\|FBN1\|FBN2\|FGD1\|FGF14\|FGFR1\|FGFR2\|FGFR3\|FKRP\|FKTN\|FMR1\|FOXG1\|FOXP1\|FTO\|FTSJ1\|G6PC3\|GABRG2\|GALE\|GAMT\|GAN\|GBA\|GBE1\|GCK\|GDI1\|GFAP\|GFM1\|GHR\|GLI3\|GLRA1\|GLUL\|GLYCTK\|GM2A\|GNAS\|GNPAT\|GNPTAB\|GNPTG\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|GRM1\|GSS\|GUSB\|GYS2\|HAX1\|HDAC4\|HDAC8\|HEPACAM\|HEXB\|HOXD10\|HPD\|HSD17B10\|HSPD1\|HUWE1\|IDS\|IGBP1\|IGF1\|IGF1R\|IL1RAPL1\|INSR\|IQSEC2\|IRX5\|ITGA7\|KCNJ10\|KCNJ11\|KCNK9\|KCNQ2\|KCTD7\|KDM5C\|KIF11\|KIF1A\|KIF21A\|KIF5A\|KIF7\|KIRREL3\|KRAS\|L1CAM\|LAMA2\|LAMP2\|LARGE\|LBR\|LHX3\|LIG4\|LMBRD1\|LRP5\|LYST\|MAGT1\|MAN1B1\|MAN2B1\|MANBA\|MAPT\|MAT1A\|MBD5\|MBTPS2\|MCCC1\|MCCC2\|MCOLN1\|MCPH1\|MECP2\|MED17\|MED23\|MEF2C\|MFSD8\|MGAT2\|MKKS\|MMADHC\|MOCS2\|MPI\|MPZ\|MRAP\|MTFMT\|MTHFR\|MTR\|MYCN\|MYO5A\|MYO7A\|NAGA\|NBN\|NDP\|NDUFA1\|NDUFAF5\|NDUFS1\|NF1\|NGF\|NHEJ1\|NHP2\|NIPBL\|NLGN3\|NPC1\|NPC2\|NPHP3\|NRXN1\|NSDHL\|NSUN2\|OFD1\|OPHN1\|ORC1\|PAFAH1B1\|PAH\|PAK3\|PAX6\|PCDH19\|PCNT\|PDE4D\|PDHX\|PDSS1\|PEX7\|PGK1\|PHF8\|PHKA2\|PHKG2\|PIGL\|PIGO\|PIGV\|PLA2G6\|PLP1\|POMGNT1\|POMT1\|POMT2\|POU1F1\|PPOX\|PQBP1\|PRICKLE1\|PRKAR1A\|PRSS12\|PTEN\|PTPN11\|PYCR1\|PYGL\|RAB39B\|RAB40AL\|RAI1\|RAPSN\|RBBP8\|RBM10\|RFX6\|RPGRIP1L\|RPS6KA3\|SACS\|SAMHD1\|SATB2\|SCN1A\|SCN8A\|SDCCAG8\|SGCA\|SGSH\|SHANK2\|SHANK3\|SHROOM4\|SIL1\|SLC16A2\|SLC20A2\|SLC25A12\|SLC25A13\|SLC25A15\|SLC2A1\|SLC2A2\|SLC35C1\|SLC46A1\|SLC4A4\|SLC5A2\|SLC5A5\|SLC6A4\|SLC6A8\|SLC7A7\|SLC9A6\|SLX4\|SMARCA4\|SMARCB1\|SMC1A\|SMS\|SNIP1\|SOBP\|SOX10\|SOX2\|SOX3\|SPR\|SPTAN1\|SPTLC1\|SRD5A3\|SRPX2\|ST3GAL3\|STAT5B\|STRA6\|STX11\|STXBP1\|SUCLG1\|SYNGAP1\|SYP\|SYT14\|TBC1D24\|TBCE\|TBX1\|TECR\|TGIF1\|TH\|THRB\|TINF2\|TMCO1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPH2\|TPK1\|TRAPPC9\|TRHR\|TSC1\|TSC2\|TSHR\|TSPAN7\|TTC37\|TTR\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|TUSC3\|TWIST1\|UBE2A\|UBE3A\|UPB1\|UPF3B\|UROC1\|USP9X\|VLDLR\|VPS13B\|WDR62\|WDR81\|WRN\|XIST\|XPNPEP3\|ZBTB16\|ZBTB24\|ZDHHC9\|ZEB2\|ZFP57\|ZFYVE26\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Not reported | Not reported | No
GTR000509436.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509436 | ABCC8\|ACY1\|ADAMTSL2\|ADSL\|AGA\|ALDH4A1\|ALDH5A1\|ALDH7A1\|AMT\|ANTXR2\|ARG1\|ARSA\|ARSB\|ASAH1\|ASPA\|ATP13A2\|BTD\|CLN3\|CLN5\|CLN6\|CLN8\|COL11A2\|COL2A1\|CTNS\|CTSA\|CTSC\|CTSD\|CTSK\|DHCR7\|DNAJC5\|DPYD\|DYM\|ETFA\|ETFB\|ETFDH\|FH\|FOLR1\|FUCA1\|GAA\|GALC\|GALNS\|GAMT\|GBA\|GCDH\|GCSH\|GLA\|GLB1\|GLDC\|GM2A\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GUSB\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|IDS\|IDUA\|L2HGDH\|LAMA2\|LAMP2\|LIPA\|LMBRD1\|MAN2B1\|MANBA\|MCOLN1\|MFSD8\|MOCS1\|MOCS2\|NAGA\|NAGLU\|NEU1\|NPC1\|NPC2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX26\|PEX3\|PEX5\|PEX6\|PGK1\|PHYH\|PPT1\|PRODH\|PSAP\|QDPR\|RAI1\|SGSH\|SLC17A5\|SLC25A15\|SLC46A1\|SMPD1\|SUMF1\|SUOX\|TCF4\|TPP1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509399.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509399 | ABAT\|ABCB1\|ABCC8\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCS1L\|BRAF\|BTD\|BUB1B\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COG1\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|EFHC1\|EFHC2\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HCN1\|HCN4\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|IDS\|IDUA\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIG4\|LRPPRC\|MAGI2\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MLC1\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDSS1\|PDSS2\|PEX1\|PEX12\|PEX14\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PHF6\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN10A\|SCN1A\|SCN1B\|SCN2A\|SCN2B\|SCN3A\|SCN3B\|SCN4A\|SCN4B\|SCN5A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC17A5\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35C1\|SLC46A1\|SLC6A5\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRPX2\|STIL\|STXBP1\|SUMF1\|SUOX\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509342.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509342 | ANKRD11\|AP1S2\|ARX\|ATRX\|AUTS2\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CDKL5\|CHD7\|CHD8\|CNTNAP2\|CNTNAP5\|CREBBP\|DHCR7\|DLGAP2\|DMD\|DOCK4\|DPP10\|DPP6\|EHMT1\|FGD1\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GABRG1\|GNA14\|GRIN2B\|GRPR\|HOXA1\|HPRT1\|IMMP2L\|KATNAL2\|KCTD13\|KDM5C\|KIRREL3\|KLHL3\|L1CAM\|LAMC3\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|NEGR1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRXN1\|NSD1\|NTNG1\|OPHN1\|PAFAH1B1\|PCDH19\|PCDH9\|PDE10A\|PHF6\|PIP5K1B\|PNKP\|PON3\|PQBP1\|PTCHD1\|PTEN\|PTPN11\|RAB39B\|RAI1\|RBFOX1\|RELN\|RPL10\|SATB2\|SCN1A\|SCN2A\|SHANK2\|SHANK3\|SLC6A4\|SLC9A6\|SLC9A9\|SMC1A\|SMG6\|SNRPN\|SOX5\|SPAST\|ST7\|STK3\|TCF4\|TSC1\|TSC2\|UBE3A\|VPS13B\|ZEB2\|ZNF507\|ZNF804A\|ZNHIT6 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cell culture\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000327662.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 327662 | AP1S2\|ARX\|ASPM\|ATRX\|AVPR1A\|BDNF\|BRAF\|CACNA1C\|CASK\|CBL\|CDKL5\|CHD7\|CNTNAP2\|CREBBP\|DCX\|DHCR7\|DMD\|EHMT1\|ERCC6\|ERCC8\|FGD1\|FGFR1\|FGFR2\|FGFR3\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|HDAC8\|HOXA1\|HPRT1\|HRAS\|KDM5C\|KMT2D\|KRAS\|L1CAM\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MEF2C\|MET\|MID1\|MKKS\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|OPHN1\|PAFAH1B1\|PCDH19\|PHF6\|PNKP\|PQBP1\|PTCH1\|PTEN\|PTPN11\|RAB39B\|RAD21\|RAF1\|RAI1\|RELN\|RPGRIP1L\|RPS6KA3\|SCN1A\|SHANK2\|SHANK3\|SHOC2\|SLC2A1\|SLC6A4\|SLC9A6\|SMC1A\|SMC3\|SOS1\|SPRED1\|TCF4\|TSC1\|TSC2\|TUBA1A\|UBE3A\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | No | No
GTR000500650.2 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500650 | 17q11.2 | FISH-metaphase | Other | Amniocytes\|Bone marrow\|Cell culture\|Chorionic villi\|Cord blood\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | No | Yes
GTR000507774.1 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 507774 | RAI1 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Bi-directional Sanger Sequence Analysis | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000504366.1 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 504366 | 17p11.2 | FISH-metaphase | Other | Peripheral (whole) blood | No | Yes
GTR000506048.2 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 506048 | 17p11.2 | FISH-metaphase | Other | Amniocytes\|Peripheral (whole) blood | No | Yes
GTR000509336.2 | Transgenomic Transgenomic Connecticut 07D0995237 509336 | ABAT\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDK\|BCS1L\|BRAF\|BTD\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCDC88C\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX10\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EOMES\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LRPPRC\|MAGI2\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFAF6\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHLRC1\|NIPBL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RBFOX1\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC4A10\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|STIL\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VDAC1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000305783.1 | UW Cytogenetic Services University of Wisconsin - Madison/WSLH Wisconsin 52D0669558 305783 | 17p11.2 | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis | Fluorescence In Situ Hybridization\|Fluorescence In Situ Hybridization\|Microarray | Amniocytes\|Amniotic fluid\|Cord blood\|Fibroblasts\|Peripheral (whole) blood | Decline to answer | Yes

Table D-10 Genetic tests for Velocardiofacial syndrome

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000512796.2 | Athena Diagnostics Inc Massachusetts 22D0069726 512796 | ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATRX\|CACNA1A\|CASK\|CASR\|CCDC88C\|CDKL5\|CHRNA2\|CHRNA4\|CHRNB2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COL18A1\|COL4A1\|CPT2\|CSTB\|CTSD\|CUL4B\|DCX\|DEPDC5\|DNAJC5\|EFHC1\|EMX2\|EPM2A\|FGD1\|FGFR3\|FKRP\|FKTN\|FLNA\|FOXG1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GPC3\|GPR56\|GRIA3\|GRIN2A\|HSD17B10\|KCNA1\|KCNJ1\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|LAMA2\|LARGE\|LBR\|LGI1\|MBD5\|ME2\|MECP2\|MEF2C\|MFSD8\|NHLRC1\|NIPBL\|NOTCH3\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PCDH19\|PEX7\|PHF6\|PIGV\|PLA2G6\|PLP1\|PNKP\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRRT2\|RAB39B\|RAB3GAP1\|RAI1\|RELN\|RNASEH2A\|RNASEH2B\|RNASEH2C\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SERPINI1\|SETBP1\|SLC25A22\|SLC2A1\|SLC4A10\|SLC9A6\|SMC1A\|SMC3\|SMS\|SNAP29\|SPTAN1\|SRPX2\|STXBP1\|SYNGAP1\|SYP\|TBC1D24\|TBX1\|TCF4\|TPP1\|TREX1\|TSC1\|TSC2\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VPS13A\|VPS13B\|WDR62\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000512797.2 | Athena Diagnostics Inc NR Massachusetts 22D0069726 512797 | ATP2A2\|ATP6V0A2\|CCDC88C\|CLCNKA\|CLCNKB\|KCNA1\|KCNJ1\|KCNJ10\|KIAA1279\|KMT2D\|LBR\|LGI1\|NIPBL\|PANK2\|PIGV\|PLA2G6\|RAI1\|SERPINI1\|SETBP1\|SMC3\|SYNGAP1\|TBX1\|TSC1\|TSC2\|VPS13A\|VPS13B | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | Yes
GTR000335344.1 | BayCare Cytogenetics Laboratory BayCare Laboratories, LLC Florida 10D2029560 335344 | HIRA | FISH-metaphase | Digital/Virtual karyotyping | Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000508280.2 | Baylor Medical Genetics Laboratories Baylor College of Medicine Texas 45D0660090 508280 | AARS2\|AASS\|ABAT\|ABCA12\|ABCA4\|ABCB11\|ABCB4\|ABCB6\|ABCB7\|ABCD1\|ABHD12\|ABHD5\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACO2\|ACOX1\|ACSF3\|ACSL4\|ADAM9\|ADCK3\|ADSL\|AFG3L2\|AGK\|AGL\|AGPS\|AGXT\|AIFM1\|AIPL1\|AK1\|AK2\|AKAP10\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|ALDOA\|ALDOB\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|ALMS1\|AMACR\|AMER1\|AMN\|AMT\|ANKH\|ANKRD26\|AP3B1\|APP\|APTX\|ARG1\|ARL6\|ASL\|ASS1\|ATIC\|ATP5E\|ATP6V0A2\|ATP7A\|ATP7B\|ATP8B1\|ATPAF2\|AUH\|B4GALT1\|B4GALT7\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|BCKDHA\|BCKDHB\|BCOR\|BCS1L\|BEST1\|BLOC1S3\|BOLA3\|BRCA1\|BTD\|C10orf2\|C12orf65\|C1QTNF5\|C2orf71\|C8orf37\|CA2\|CA4\|CABP4\|CACNA1F\|CACNA2D4\|CASP8\|CAT\|CBS\|CC2D2A\|CCDC28B\|CCDC39\|CDH23\|CDHR1\|CEP290\|CERKL\|CHAT\|CHM\|CISD2\|CLCN7\|CLN3\|CLRN1\|CNGA1\|CNGA3\|CNGB1\|CNGB3\|COG1\|COG7\|COG8\|COL1A1\|COL1A2\|COL2A1\|COL3A1\|COL5A1\|COL5A2\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|CPOX\|CPS1\|CPT1A\|CPT2\|CRB1\|CRTAP\|CRX\|CRYAB\|CTSA\|CTSD\|CTSK\|CUBN\|CYB5A\|CYB5R3\|CYBA\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP17A1\|CYP1B1\|CYP24A1\|CYP27A1\|CYP27B1\|CYP4V2\|D2HGDH\|DARS2\|DBT\|DDOST\|DFNB31\|DGUOK\|DHDDS\|DHODH\|DIABLO\|DLAT\|DLD\|DMGDH\|DNAJC19\|DNM1L\|DPM1\|DPM3\|DSP\|DTNBP1\|EFEMP1\|ELAC2\|ELN\|ELOVL4\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|EYA1\|EYA4\|EYS\|FAH\|FAM161A\|FAM20C\|FASTKD2\|FBLN5\|FBN1\|FBP1\|FECH\|FH\|FKBP10\|FLVCR1\|FOXC1\|FOXL2\|FOXRED1\|FRMD7\|FSCN2\|FXN\|FYCO1\|FZD4\|G6PC\|GAA\|GAD1\|GALC\|GALE\|GALK1\|GALNS\|GALT\|GAMT\|GARS\|GATM\|GBE1\|GCDH\|GCK\|GCKR\|GCSH\|GFER\|GFM1\|GIF\|GJA3\|GK\|GLB1\|GLDC\|GLRX5\|GLUD1\|GLYCTK\|GM2A\|GNAT1\|GNAT2\|GNE\|GNPTAB\|GNS\|GOT1\|GPD1\|GPD2\|GPI\|GPR143\|GPR98\|GPX1\|GRK1\|GRM6\|GRN\|GSN\|GUCA1A\|GUCA1B\|GUCY2D\|GUSB\|GYS1\|GYS2\|HADHA\|HADHB\|HAGH\|HARS\|HAX1\|HBB\|HCCS\|HESX1\|HEXA\|HEXB\|HGSNAT\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HNF1A\|HNF1B\|HP\|HPRT1\|HPS1\|HPS3\|HPS4\|HPS5\|HPS6\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH2\|IDH3B\|IMPDH1\|IMPG2\|INPP5E\|INVS\|IQCB1\|ISCU\|IVD\|JAG1\|KARS\|KCNJ13\|KCNV2\|KIF1B\|KIF21A\|KLHL7\|KRT12\|KRT3\|KRT5\|L2HGDH\|LCA5\|LDHA\|LDHB\|LEMD3\|LEPRE1\|LIAS\|LMBRD1\|LMX1B\|LPIN1\|LRAT\|LRP5\|LRPPRC\|MAN2B1\|MANBA\|MAOA\|MC1R\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MEF2A\|MEN1\|MERTK\|MFN2\|MFRP\|MGAT2\|MKKS\|MKS1\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MPDU1\|MPI\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MSRB3\|MTHFR\|MTO1\|MTPAP\|MTR\|MTRR\|MUT\|MUTYH\|MYO7A\|MYOC\|NAGLU\|NAGS\|NCOA4\|NDP\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFAF5\|NDUFAF6\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NEFH\|NEUROD1\|NFU1\|NHS\|NME1\|NPHP1\|NPHP3\|NPHP4\|NRL\|NT5C3A\|NUBPL\|NYX\|OAT\|OCA2\|OCRL\|OGDH\|OGG1\|OPA1\|OPA3\|OPN1LW\|OPN1MW\|OPTN\|OSTM1\|OTC\|OTX2\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PAX2\|PAX6\|PC\|PCCA\|PCCB\|PCDH15\|PCK2\|PDE6A\|PDE6B\|PDE6C\|PDE6G\|PDHA1\|PDHB\|PDP1\|PDSS1\|PDSS2\|PDZD7\|PFKM\|PGAM2\|PGM1\|PHB\|PHKA1\|PHKA2\|PHKB\|PHKG2\|PHOX2A\|PHYH\|PINK1\|PITPNM3\|PITX2\|PITX3\|PLA2G2A\|PLOD2\|PLOD3\|PMM2\|PNKD\|PNPLA2\|POLG\|POLG2\|PPARG\|PPARGC1B\|PPIB\|PPOX\|PPP2R1B\|PRCD\|PRKCG\|PRODH\|PROM1\|PRPF31\|PRPF6\|PRPF8\|PRPH2\|PSAP\|PSEN1\|PTRF\|PTS\|PUS1\|PYCR1\|PYGL\|PYGM\|QDPR\|RAF1\|RARS2\|RAX\|RB1\|RD3\|RDH12\|RDH5\|REEP1\|RET\|RFT1\|RGR\|RGS9\|RHO\|RILP\|RIMS1\|RLBP1\|RNASEL\|RP1\|RP1L1\|RP2\|RP9\|RPE65\|RPGR\|RPGRIP1\|RPL35A\|RPS14\|RRM2B\|RS1\|SAG\|SARDH\|SARS2\|SCO2\|SCP2\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SECISBP2\|SEMA4A\|SEPT9\|SERPINF1\|SGSH\|SHH\|SIX6\|SLC16A1\|SLC22A4\|SLC22A5\|SLC24A1\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC26A4\|SLC34A1\|SLC35A1\|SLC35C1\|SLC37A4\|SLC39A13\|SLC3A1\|SLC45A2\|SLC9A3R1\|SLC9A6\|SMPD1\|SNCB\|SNRNP200\|SOD1\|SOD2\|SOST\|SOX2\|SP7\|SPATA7\|SPG7\|SPR\|SPTLC2\|SQSTM1\|SRD5A3\|STAR\|STAT1\|STAT3\|STRA6\|STXBP1\|SUCLA2\|SUCLG1\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TCN2\|TEAD1\|TGFB1\|TGFBI\|TIMM8A\|TIMP3\|TK2\|TLR3\|TLR4\|TMEM126A\|TMEM127\|TMEM67\|TMEM70\|TNFRSF11A\|TNFRSF11B\|TNFSF11\|TOPORS\|TP53\|TPP1\|TRIM32\|TRMU\|TRPM1\|TSFM\|TSPAN12\|TTC19\|TTC8\|TUBA1A\|TUBB3\|TUFM\|TULP1\|TUSC3\|TYMP\|TYR\|TYROBP\|TYRP1\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|USH1C\|USH1G\|USH2A\|VCP\|VHL\|VSX1\|WFS1\|WT1\|WWOX\|XDH\|XPNPEP3\|YARS2\|ZEB1\|ZFHX3\|ZNF513 | Deletion/duplication analysis | Comparative Genomic Hybridization | NR | NR | NR
GTR000257087.2 | Center for Human Genetics Laboratory University Hospitals - University Hospitals Laboratory Service Foundation Ohio 36D0656024 257087 | 22q11.2 | FISH-metaphase | Other | Amniocytes\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000206879.1 | Center for Human Genetics, Inc NR Massachusetts 22D0650242 206879 | 22q11.2 | FISH-interphase\|FISH-metaphase | Fluorescence in situ Hybridization (FISH)\|Fluorescence in situ Hybridization (FISH) | NR | Decline to answer | No
GTR000295251.1 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 295251 | 22q11.2 | FISH-metaphase | Metaphase FISH analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | No
GTR000500883.8 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500883 | ABAT\|ABCC2\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|AKT3\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASAH1\|ASPA\|ASPM\|ATIC\|ATN1\|ATP1A2\|ATP1A3\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BRAF\|BRAT1\|BRD2\|BTD\|BUB1B\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT1A\|CPT2\|CSTB\|CTSA\|CTSD\|CTSF\|CUL4B\|CYP1B1\|CYP2A6\|CYP2B6\|CYP2C19\|CYP2C9\|CYP2D6\|CYP2R1\|CYP2U1\|CYP3A5\|DBT\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FAAH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FOXH1\|FUCA1\|GABBR2\|GABRA1\|GABRA2\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDH2\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIAS\|LIG4\|LRPPRC\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED12\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NGLY1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPA1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PIK3CA\|PIK3R2\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|RTTN\|SAMHD1\|SCARB2\|SCN10A\|SCN11A\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGCE\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SNIP1\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|ST3GAL5\|STIL\|STRADA\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TRPM6\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | No
GTR000514882.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 514882 | ADSL\|AFF2\|ANK3\|AP1S2\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|ARFGEF2\|ARX\|ATRX\|BBS4\|BCKDK\|BCOR\|BDNF\|BRAF\|C12orf57\|CA8\|CACNA1C\|CACNG2\|CASK\|CC2D1A\|CDH15\|CDKL5\|CHD7\|CLIC2\|CNTNAP2\|COMT\|CRBN\|CREBBP\|CTCF\|CTNNB1\|D2HGDH\|DCX\|DDHD2\|DHCR7\|DMD\|EHMT1\|EP300\|ERLIN2\|FGD1\|FGF8\|FMR1\|FOLR1\|FOXG1\|FOXP1\|FOXP2\|GABRB3\|GATAD2B\|GNS\|GRIA3\|GRIK2\|GRIN1\|GRIN2B\|HCFC1\|HDAC8\|HGSNAT\|HOXA1\|HPRT1\|HRAS\|HTR2A\|HYDIN\|IDH2\|KCNJ10\|KDM5C\|KIAA2022\|KRAS\|L1CAM\|LINS\|LRP2\|MAN1B1\|MAP2K1\|MAP2K2\|MBD5\|MECP2\|MED12\|MED23\|MEF2C\|MET\|MID1\|MKKS\|NAGLU\|NF1\|NHS\|NIPBL\|NLGN3\|NLGN4X\|NRAS\|NRXN1\|NSD1\|NSDHL\|NSUN2\|OCRL\|OPHN1\|PAFAH1B1\|PCDH19\|PCNT\|PHF6\|PLP1\|PNKP\|PQBP1\|PRSS12\|PTEN\|PTPN11\|RAB39B\|RAF1\|RAI1\|RELN\|RPS6KA3\|SCN1A\|SGSH\|SHANK2\|SHANK3\|SHOC2\|SHROOM4\|SLC25A1\|SLC2A1\|SLC6A8\|SLC9A6\|SLC9A9\|SMARCB1\|SMC1A\|SMC3\|SNRPN\|SOBP\|SOS1\|SRPX2\|TBX1\|TCF4\|TECR\|TRAPPC9\|TSC1\|TSC2\|TUSC3\|UBE2A\|UBE3A\|UPF3B\|VLDLR\|VPS13B\|ZEB2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Saliva\|Serum\|Skin | No | No
GTR000500619.2 | Cytogenetics and Microarray Laboratory Kennedy Krieger Institute Maryland 21D0649789 500619 | 22q11.2\|Yp11.3 | Fluorescence in situ hybridization (FISH) | Other | Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood | Decline to answer | Yes
GTR000325584.2 | Cytogenetics and Molecular Genetics Laboratory Mercy St. Vincent Medical Center Ohio 36D0965797 325584 | 22q11.2 | FISH-interphase\|FISH-metaphase | FISH\|FISH | Amniocytes\|Amniotic fluid\|Fetal blood\|Peripheral (whole) blood | Decline to answer | Yes
GTR000316013.2 | Cytogenetics and Molecular Pathology Laboratory DLP Marquette General Hospital, LLC Michigan 23D1062707 316013 | HIRA | FISH-interphase\|FISH-metaphase\|Karyotyping | FISH LSI HIRA/SHANK3\|FISH LSI HIRA/SHANK3\|G-banding | Buccal swab\|Cell culture\|Cord blood\|Peripheral (whole) blood | No | Yes
GTR000013538.2 | Cytogenetics Laboratory Indiana University School of Medicine Indiana 15D0647198 13538 | 22q11.2 | FISH-interphase\|FISH-metaphase | Fluorescence in situ hybridization (FISH)\|Fluorescence in situ hybridization (FISH) | Amniocytes\|Amniotic fluid\|Bone marrow\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin\|Urine | Decline to answer | Yes
GTR000032597.1 | Cytogenetics Laboratory SUNY Upstate Medical University New York 33D0654590 32597 | 22q11.2 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Yes | Yes
GTR000500042.2 | Cytogenetics Laboratory ARUP Laboratories, Inc. Utah 46D0523979 500042 | 15q11.2-q13\|17p11.2\|17p13.3\|22q11.2\|22q13.3\|4p16.3\|5p15.2\|7q11.23\|Xp22.3\|Yp11.3 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000501825.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501825 | 22q11.2 | FISH-interphase | Fluorescence In Situ Hybridization | Fetal blood\|Peripheral (whole) blood | Decline to answer | No
GTR000512325.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512325 | ABCC9\|ACTA2\|ACTC1\|ACTN2\|ACVRL1\|AKAP9\|ANK2\|ANKRD1\|BAG3\|BMPR2\|BRAF\|CACNA1C\|CACNB2\|CASQ2\|CAV1\|CAV3\|CBS\|COL3A1\|COL5A1\|COL5A2\|CRYAB\|CSRP3\|DES\|DMD\|DSC2\|DSG2\|DSP\|DTNA\|EMD\|ENG\|FBN1\|FBN2\|FHL2\|FKTN\|FLNA\|GATAD1\|GLA\|GPD1L\|HCN4\|HRAS\|JPH2\|JUP\|KCNE1\|KCNE2\|KCNE3\|KCNH2\|KCNJ2\|KCNJ5\|KCNJ8\|KCNQ1\|KRAS\|LAMA4\|LAMP2\|LDB3\|LMNA\|MAP2K1\|MAP2K2\|MED12\|MYBPC3\|MYH11\|MYH6\|MYH7\|MYL2\|MYL3\|MYLK2\|MYOZ2\|MYPN\|NEBL\|NEXN\|NKX2-5\|NR2F2\|NRAS\|PKP2\|PLN\|PRKAG2\|PTPN11\|RAF1\|RANGRF\|RBM20\|RYR2\|SCN1B\|SCN3B\|SCN4B\|SCN5A\|SGCD\|SKI\|SLC2A10\|SMAD3\|SNTA1\|SOS1\|TAZ\|TCAP\|TGFB2\|TGFBR1\|TGFBR2\|TMEM43\|TMPO\|TNNC1\|TNNI3\|TNNT2\|TPM1\|TTN\|TTR\|VCL | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood | No | No
GTR000512328.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512328 | AKAP9\|ANK2\|CACNA1C\|CACNB2\|CASQ2\|DSC2\|DSG2\|DSP\|GPD1L\|HCN4\|JUP\|KCNE1\|KCNE2\|KCNE3\|KCNH2\|KCNJ2\|KCNJ5\|KCNJ8\|KCNQ1\|NKX2-5\|PKP2\|RANGRF\|RYR2\|SCN1B\|SCN3B\|SCN4B\|SCN5A\|SNTA1\|TMEM43 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512415.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512415 | ACVR2B\|AHI1\|AIPL1\|ARL13B\|ARL6\|ATXN10\|B9D1\|B9D2\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|C2orf71\|C5orf42\|CC2D2A\|CCDC28B\|CCDC39\|CCDC40\|CDH23\|CEP164\|CEP290\|CEP41\|CFTR\|CLRN1\|CRB1\|CRELD1\|CRX\|DFNB31\|DNAAF1\|DNAAF2\|DNAAF3\|DNAH11\|DNAH5\|DNAI1\|DNAI2\|DNAL1\|DYNC2H1\|EVC\|EVC2\|FOXH1\|GDF1\|GLIS2\|GPR98\|GUCY2D\|HYLS1\|IFT43\|IFT80\|IMPDH1\|INVS\|IQCB1\|KCNJ13\|KIF7\|LCA5\|LEFTY2\|LRAT\|MKKS\|MKS1\|MYO7A\|NEK1\|NEK8\|NKX2-5\|NME8\|NODAL\|NPHP1\|NPHP3\|NPHP4\|OFD1\|PCDH15\|PKD2\|PKHD1\|RD3\|RDH12\|RPE65\|RPGR\|RPGRIP1\|RPGRIP1L\|RSPH4A\|RSPH9\|SCNN1A\|SCNN1B\|SCNN1G\|SDCCAG8\|SPATA7\|TCTN1\|TCTN2\|TMEM138\|TMEM216\|TMEM231\|TMEM237\|TMEM67\|TOPORS\|TRIM32\|TSC1\|TSC2\|TTC21B\|TTC8\|TULP1\|UMOD\|USH1C\|USH1G\|USH2A\|VHL\|WDPCP\|WDR19\|WDR35\|XPNPEP3\|ZIC3\|ZNF423 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512588.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512588 | ACTB\|ACTG1\|AHI1\|ARFGEF2\|ARX\|CASK\|CC2D2A\|CEP290\|CEP41\|CHMP1A\|DCX\|EOMES\|EXOSC3\|FKRP\|FKTN\|FLNA\|GPR56\|KIAA1279\|KIF7\|LAMC3\|LARGE\|MKS1\|NPHP1\|OPHN1\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|PQBP1\|RAB3GAP1\|RAB3GAP2\|RARS2\|RELN\|RPGRIP1L\|RTTN\|SRPX2\|TMEM138\|TMEM216\|TMEM237\|TMEM67\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|VLDLR\|VRK1\|WDR62 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512596.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512596 | ABCC8\|AGPAT2\|AKT2\|BLK\|BMP15\|BSCL2\|CHD7\|CIDEC\|CISD2\|CYP17A1\|CYP19A1\|EIF2AK3\|FGF8\|FGFR1\|FIGLA\|FOXP3\|FSHR\|GATA6\|GCK\|GDF9\|GLIS3\|GNRH1\|GNRHR\|HADH\|HNF1A\|HNF1B\|HNF4A\|IER3IP1\|INS\|INSR\|KCNJ11\|KISS1\|KISS1R\|KLF11\|LHCGR\|LMNA\|NEUROD1\|NOBOX\|NR0B1\|NR5A1\|NSMF\|PAX4\|PDX1\|POR\|PPARG\|PROK2\|PROKR2\|PSMC3IP\|PTF1A\|PTRF\|RFX6\|SLC2A2\|TAC3\|TACR3\|TBC1D4\|WFS1\|ZMPSTE24 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000512608.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 512608 | ACTB\|ACTG1\|ADSL\|AHI1\|ALDH7A1\|ARFGEF2\|ARHGEF9\|ARX\|ASPM\|ATP1A2\|ATP6AP2\|ATR\|ATRX\|BCKDK\|CACNB4\|CASC5\|CASK\|CC2D2A\|CDC6\|CDK5RAP2\|CDKL5\|CDT1\|CENPJ\|CEP135\|CEP152\|CEP290\|CEP41\|CEP63\|CHMP1A\|CHRNA2\|CHRNA4\|CHRNB2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|CPA6\|CSTB\|CTSD\|DCX\|DHCR7\|DISP1\|DNAJC5\|EFHC1\|EHMT1\|EOMES\|EPM2A\|EXOSC3\|FGF8\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FOXH1\|GABRA1\|GABRG2\|GAMT\|GATM\|GLI2\|GOSR2\|GPR56\|GPR98\|GRIN2A\|GRIN2B\|KCNJ10\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KIAA1279\|KIF7\|LAMC3\|LARGE\|LARP7\|LGI1\|LIAS\|MAGI2\|MAPK10\|MBD5\|MCPH1\|MECP2\|MEF2C\|MFSD8\|MKS1\|MYCN\|NDE1\|NHLRC1\|NIN\|NODAL\|NPHP1\|NRXN1\|OPHN1\|ORC4\|ORC6\|PAFAH1B1\|PCDH19\|PCNT\|PLCB1\|PNKP\|PNPO\|POC1A\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRRT2\|PTCH1\|RAB18\|RAB3GAP1\|RAB3GAP2\|RARS2\|RBBP8\|RELN\|RPGRIP1L\|RTTN\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN8A\|SCN9A\|SHH\|SIX3\|SLC19A3\|SLC25A19\|SLC25A22\|SLC2A1\|SLC9A6\|SPTAN1\|SRPX2\|ST3GAL3\|ST3GAL5\|STIL\|STXBP1\|SYN1\|TBC1D24\|TCF4\|TGIF1\|TMEM138\|TMEM216\|TMEM237\|TMEM67\|TPP1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|UBE3A\|VLDLR\|VRK1\|WDR62\|ZEB2\|ZIC2\|ZNF335 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | No | No
GTR000506437.10 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 506437 | ABCC9\|ACTC1\|ACTN2\|AKAP9\|ANK2\|ANKRD1\|BAG3\|CACNA1C\|CACNA2D1\|CACNB2\|CALR3\|CASQ2\|CAV3\|COX15\|CRYAB\|CSRP3\|DES\|DMD\|DOLK\|DSC2\|DSG2\|DSP\|DTNA\|EMD\|EYA4\|FKTN\|FLNA\|FXN\|GAA\|GATA4\|GATAD1\|GJA5\|GLA\|GPD1L\|HCN4\|ILK\|JAG1\|JPH2\|JUP\|KCNA5\|KCNE1\|KCNE2\|KCNE3\|KCNH2\|KCNJ2\|KCNJ5\|KCNJ8\|KCNQ1\|LAMA4\|LAMP2\|LDB3\|LMNA\|MRPL3\|MURC\|MYBPC3\|MYH6\|MYH7\|MYL2\|MYL3\|MYLK2\|MYOM1\|MYOZ2\|MYPN\|NDUFAF1\|NEBL\|NEXN\|NKX2-5\|NPPA\|PDLIM3\|PKP2\|PLN\|PRKAG2\|PSEN2\|PTPN11\|RAF1\|RBM20\|RYR2\|SCN1B\|SCN3B\|SCN4B\|SCN5A\|SDHA\|SGCD\|SNTA1\|SYNE1\|TAZ\|TBX1\|TBX5\|TCAP\|TGFB3\|TMEM43\|TMPO\|TNNC1\|TNNI3\|TNNT2\|TPM1\|TTN\|TTR\|TXNRD2\|VCL | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509335.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509335 | ABCC9\|GATA4\|GATA6\|GJA5\|HCN4\|KCNA5\|KCND3\|KCNE1\|KCNE2\|KCNH2\|KCNJ2\|KCNJ5\|KCNJ8\|KCNQ1\|LMNA\|NPPA\|NUP155\|RYR2\|SCN1B\|SCN2B\|SCN3B\|SCN4B\|SCN5A | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509399.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509399 | ABAT\|ABCB1\|ABCC8\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG12\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|APTX\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP6AP2\|ATP6V0A2\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCS1L\|BRAF\|BTD\|BUB1B\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCL2\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLCNKA\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CNTNAP2\|COG1\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|EFHC1\|EFHC2\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FLVCR2\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GNE\|GNPTAB\|GNPTG\|GNS\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HCN1\|HCN4\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|IDS\|IDUA\|KAT6B\|KCNA1\|KCNJ1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNV2\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LIG4\|LRPPRC\|MAGI2\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MLC1\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHEJ1\|NHLRC1\|NIPBL\|NODAL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDSS1\|PDSS2\|PEX1\|PEX12\|PEX14\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PHF6\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN10A\|SCN1A\|SCN1B\|SCN2A\|SCN2B\|SCN3A\|SCN3B\|SCN4A\|SCN4B\|SCN5A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC17A5\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35C1\|SLC46A1\|SLC6A5\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRPX2\|STIL\|STXBP1\|SUMF1\|SUOX\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|UBE3A\|VANGL1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509442.11 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509442 | ABCC6\|ABCD1\|ABCG5\|ACAT1\|ACOX1\|ACSL4\|ACY1\|ADAR\|ADSL\|AFF2\|AFP\|AGL\|AGT\|AGTR2\|AHI1\|AIFM1\|ALDH18A1\|ALDH4A1\|ALG11\|ALG12\|ALG6\|ALX4\|AMER1\|AP1S1\|AP1S2\|AP3B1\|AP4B1\|AP4E1\|AP4M1\|AP4S1\|APOB\|AQP7\|AR\|ARG1\|ARHGEF6\|ARID1A\|ARID1B\|ARX\|ASPM\|ASS1\|ATL1\|ATM\|ATP13A2\|ATP1A2\|ATP6AP2\|ATP7A\|ATRX\|AUH\|AVP\|AVPR2\|BBS9\|BCS1L\|BIN1\|BRCA2\|BRIP1\|BRWD3\|BUB1B\|CACNG2\|CAMTA1\|CANT1\|CASK\|CBS\|CC2D1A\|CC2D2A\|CCDC88C\|CDH15\|CDKL5\|CDKN1C\|CEP290\|CEP41\|CEP57\|CHD7\|CHRNA4\|CLN3\|CNTNAP2\|COG5\|COG7\|COL1A2\|CP\|CPA6\|CPS1\|CRADD\|CRBN\|CTC1\|CTNNB1\|CTSA\|CUL4B\|CYB5R3\|CYP27A1\|D2HGDH\|DARS2\|DBT\|DHCR24\|DHCR7\|DIP2B\|DLG3\|DMD\|DPYD\|DYNC1H1\|DYRK1A\|EBP\|EFNB1\|EHMT1\|ELOVL4\|ERCC2\|ERCC3\|ERCC5\|ERCC6\|ERCC8\|F5\|FAM126A\|FANCG\|FBLN5\|FBN1\|FBN2\|FGD1\|FGF14\|FGFR1\|FGFR2\|FGFR3\|FKRP\|FKTN\|FMR1\|FOXG1\|FOXP1\|FTO\|FTSJ1\|G6PC3\|GABRG2\|GALE\|GAMT\|GAN\|GBA\|GBE1\|GCK\|GDI1\|GFAP\|GFM1\|GHR\|GLI3\|GLRA1\|GLUL\|GLYCTK\|GM2A\|GNAS\|GNPAT\|GNPTAB\|GNPTG\|GRIA3\|GRIK2\|GRIN1\|GRIN2A\|GRIN2B\|GRM1\|GSS\|GUSB\|GYS2\|HAX1\|HDAC4\|HDAC8\|HEPACAM\|HEXB\|HOXD10\|HPD\|HSD17B10\|HSPD1\|HUWE1\|IDS\|IGBP1\|IGF1\|IGF1R\|IL1RAPL1\|INSR\|IQSEC2\|IRX5\|ITGA7\|KCNJ10\|KCNJ11\|KCNK9\|KCNQ2\|KCTD7\|KDM5C\|KIF11\|KIF1A\|KIF21A\|KIF5A\|KIF7\|KIRREL3\|KRAS\|L1CAM\|LAMA2\|LAMP2\|LARGE\|LBR\|LHX3\|LIG4\|LMBRD1\|LRP5\|LYST\|MAGT1\|MAN1B1\|MAN2B1\|MANBA\|MAPT\|MAT1A\|MBD5\|MBTPS2\|MCCC1\|MCCC2\|MCOLN1\|MCPH1\|MECP2\|MED17\|MED23\|MEF2C\|MFSD8\|MGAT2\|MKKS\|MMADHC\|MOCS2\|MPI\|MPZ\|MRAP\|MTFMT\|MTHFR\|MTR\|MYCN\|MYO5A\|MYO7A\|NAGA\|NBN\|NDP\|NDUFA1\|NDUFAF5\|NDUFS1\|NF1\|NGF\|NHEJ1\|NHP2\|NIPBL\|NLGN3\|NPC1\|NPC2\|NPHP3\|NRXN1\|NSDHL\|NSUN2\|OFD1\|OPHN1\|ORC1\|PAFAH1B1\|PAH\|PAK3\|PAX6\|PCDH19\|PCNT\|PDE4D\|PDHX\|PDSS1\|PEX7\|PGK1\|PHF8\|PHKA2\|PHKG2\|PIGL\|PIGO\|PIGV\|PLA2G6\|PLP1\|POMGNT1\|POMT1\|POMT2\|POU1F1\|PPOX\|PQBP1\|PRICKLE1\|PRKAR1A\|PRSS12\|PTEN\|PTPN11\|PYCR1\|PYGL\|RAB39B\|RAB40AL\|RAI1\|RAPSN\|RBBP8\|RBM10\|RFX6\|RPGRIP1L\|RPS6KA3\|SACS\|SAMHD1\|SATB2\|SCN1A\|SCN8A\|SDCCAG8\|SGCA\|SGSH\|SHANK2\|SHANK3\|SHROOM4\|SIL1\|SLC16A2\|SLC20A2\|SLC25A12\|SLC25A13\|SLC25A15\|SLC2A1\|SLC2A2\|SLC35C1\|SLC46A1\|SLC4A4\|SLC5A2\|SLC5A5\|SLC6A4\|SLC6A8\|SLC7A7\|SLC9A6\|SLX4\|SMARCA4\|SMARCB1\|SMC1A\|SMS\|SNIP1\|SOBP\|SOX10\|SOX2\|SOX3\|SPR\|SPTAN1\|SPTLC1\|SRD5A3\|SRPX2\|ST3GAL3\|STAT5B\|STRA6\|STX11\|STXBP1\|SUCLG1\|SYNGAP1\|SYP\|SYT14\|TBC1D24\|TBCE\|TBX1\|TECR\|TGIF1\|TH\|THRB\|TINF2\|TMCO1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPH2\|TPK1\|TRAPPC9\|TRHR\|TSC1\|TSC2\|TSHR\|TSPAN7\|TTC37\|TTR\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|TUSC3\|TWIST1\|UBE2A\|UBE3A\|UPB1\|UPF3B\|UROC1\|USP9X\|VLDLR\|VPS13B\|WDR62\|WDR81\|WRN\|XIST\|XPNPEP3\|ZBTB16\|ZBTB24\|ZDHHC9\|ZEB2\|ZFP57\|ZFYVE26\|ZIC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | NR | NR
GTR000509445.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509445 | ABCC8\|AKT2\|BLK\|CEL\|CISD2\|CP\|EIF2AK3\|FOXP3\|GATA6\|GCK\|GLIS3\|GLUD1\|HADH\|HNF1A\|HNF1B\|HNF4A\|IER3IP1\|INS\|INSR\|KCNJ11\|NEUROD1\|NEUROG3\|PAX4\|PDX1\|PTF1A\|RFX6\|SLC2A2\|WFS1\|ZFP57 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000508585.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 508585 | ACTB\|ACTG1\|ARX\|DCX\|FKRP\|FKTN\|GPR56\|KIAA1279\|LAMC3\|LARGE\|OCLN\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|RAB18\|RAB3GAP1\|RAB3GAP2\|RELN\|RTTN\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|VLDLR\|WDR62 | Deletion/duplication analysis | Microarray | Buccal swab\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000508586.1 | Genetic Services Laboratory University of Chicago Illinois 14D0917593 508586 | ACTB\|ACTG1\|ARX\|DCX\|FKRP\|FKTN\|GPR56\|KIAA1279\|LAMC3\|LARGE\|OCLN\|PAFAH1B1\|POMGNT1\|POMT1\|POMT2\|RAB18\|RAB3GAP1\|RAB3GAP2\|RELN\|RTTN\|TUBA1A\|TUBA8\|TUBB2B\|TUBB3\|VLDLR\|WDR62 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Cell culture\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509244.1 | Genetics Laboratory Shodair Children’s Hospital Montana 27D0652530 509244 | Chromosome 22 | FISH-metaphase | Metaphase FISH | Cord blood\|Fetal blood\|Peripheral (whole) blood | Decline to answer | Yes
GTR000500919.1 | Heart Institute Diagnostic Lab Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 500919 | TBX1 | Mutation scanning of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | Decline to answer | No
GTR000053116.1 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 53116 | 22q11.2 | FISH-interphase\|FISH-metaphase | Fluorescence in situ hybridization\|Fluorescence in situ hybridization | Amniocytes\|Amniotic fluid\|Buccal swab\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Paraffin block\|Peripheral (whole) blood\|Product of conception (POC) | No | Yes
GTR000515046.3 | Illumina Clinical Services Laboratory Illumina California 05D1092911 515046 | NR | NR | NR | NR | NR | NR
GTR000508888.1 | Michigan Medical Genetics Laboratories University of Michigan Michigan 23D0366712 508888 | Human genome | Deletion/duplication analysis | Microarray\|Real Time Quantitative PCR | Peripheral (whole) blood | Decline to answer | Yes
GTR000500635.2 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500635 | 22q11.2 | FISH-metaphase | Other | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Dried blood spot (DBS) card\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | No | Yes
GTR000335353.3 | MitoMed Diagnostic Laboratory UCI California 05D1034314 335353 | TBX1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | Buccal swab\|Cell culture\|Cord blood\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood | No | Yes
GTR000501119.2 | Molecular Genetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 501119 | ADA\|CD3D\|CD3E\|DCLRE1C\|FOXN1\|IL2RG\|IL7R\|JAK3\|LIG4\|NHEJ1\|ORAI1\|PNP\|PTPRC\|RAG1\|RAG2\|RMRP\|STAT5B\|STIM1\|TBX1\|ZAP70 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | NR | Decline to answer | Yes
GTR000509589.1 | Molecular Genetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 509589 | TBX1 | Sequence analysis of the entire coding region | Bi-directional Sanger Sequence Analysis | NR | Decline to answer | Yes
GTR000505776.3 | PreventionGenetics PreventionGenetics Wisconsin 52D2065132 505776 | ACVR2B\|AHI1\|ANKS6\|ARL13B\|ARL6\|B9D1\|B9D2\|BBS1\|BBS10\|BBS12\|BBS2\|BBS4\|BBS5\|BBS7\|BBS9\|C5orf42\|CC2D2A\|CCDC103\|CCDC11\|CCDC114\|CCDC39\|CCDC40\|CEP164\|CEP290\|CEP41\|CFTR\|DNAAF1\|DNAAF2\|DNAAF3\|DNAH11\|DNAH5\|DNAI1\|DNAI2\|DNAL1\|FOXH1\|GDF1\|GLIS2\|HEATR2\|INPP5E\|INVS\|IQCB1\|KIF7\|LEFTY2\|LRRC6\|MKKS\|MKS1\|NEK8\|NKX2-5\|NME8\|NODAL\|NPHP1\|NPHP3\|NPHP4\|OFD1\|RPGR\|RPGRIP1L\|RSPH4A\|RSPH9\|SDCCAG8\|TCTN1\|TCTN2\|TCTN3\|TMEM138\|TMEM216\|TMEM231\|TMEM237\|TMEM67\|TRIM32\|TTC21B\|TTC8\|WDPCP\|WDR19\|ZIC3\|ZNF423 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Comparative Genomic Hybridization\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Amniocytes\|Amniotic fluid\|Bone marrow\|Buccal swab\|Cell culture\|Cell-free DNA\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Product of conception (POC)\|Saliva\|Skin\|Sputum\|White blood cell prep | No | Yes
GTR000504359.1 | Quest Diagnostics Nichols Institute Chantilly NR Virginia 49D0221801 504359 | 22q11.21 | FISH-metaphase | Other | Peripheral (whole) blood | No | Yes
GTR000506041.2 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 506041 | 22q11.21 | FISH-metaphase | Other | Amniocytes\|Chorionic villi\|Peripheral (whole) blood | No | Yes
GTR000501985.3 | Sequenom Center for Molecular Medicine – San Diego Sequenom CMM California 05D2015356 501985 | 1p36\|22q11.2\|5p15.2\|Chromosome 13\|Chromosome 15\|Chromosome 16\|Chromosome 18\|Chromosome 21\|Chromosome 22\|Sex chromosome X\|Sex chromosome Y | Targeted variant analysis | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000509336.2 | Transgenomic Transgenomic Connecticut 07D0995237 509336 | ABAT\|ABCC8\|ACOX1\|ACY1\|ADCK3\|ADSL\|AGA\|AHI1\|ALDH4A1\|ALDH5A1\|ALDH7A1\|ALG1\|ALG11\|ALG12\|ALG13\|ALG2\|ALG3\|ALG6\|ALG8\|ALG9\|AMT\|ARFGEF2\|ARG1\|ARHGEF9\|ARL13B\|ARSA\|ARSB\|ARX\|ASPA\|ASPM\|ATIC\|ATP1A2\|ATP2A2\|ATP5A1\|ATP6AP2\|ATP6V0A2\|ATP7A\|ATPAF2\|ATR\|ATRX\|B4GALT1\|BCKDK\|BCS1L\|BRAF\|BTD\|C12orf57\|C12orf65\|CACNA1A\|CACNA1H\|CACNB4\|CASK\|CASR\|CBL\|CC2D2A\|CCDC88C\|CDK5RAP2\|CDKL5\|CDON\|CENPJ\|CEP152\|CEP290\|CHD2\|CHRNA2\|CHRNA4\|CHRNB2\|CLCN2\|CLN3\|CLN5\|CLN6\|CLN8\|CNTN2\|CNTNAP2\|COG1\|COG4\|COG5\|COG6\|COG7\|COG8\|COL18A1\|COL4A1\|COQ2\|COQ9\|COX10\|COX15\|CPT2\|CSTB\|CTSA\|CTSD\|CUL4B\|DCX\|DDC\|DDOST\|DEPDC5\|DHCR7\|DLD\|DOLK\|DPAGT1\|DPM1\|DPM3\|DPYD\|DYRK1A\|EFHC1\|EIF2B1\|EIF2B2\|EIF2B3\|EIF2B4\|EIF2B5\|EMX2\|EOMES\|EPM2A\|ETFA\|ETFB\|ETFDH\|FGD1\|FGF8\|FGFR3\|FH\|FKRP\|FKTN\|FLNA\|FOLR1\|FOXG1\|FUCA1\|GABRA1\|GABRB3\|GABRD\|GABRG2\|GALC\|GALNS\|GAMT\|GATM\|GCDH\|GCSH\|GFAP\|GLB1\|GLDC\|GLI2\|GLI3\|GLRA1\|GLRB\|GLUD1\|GLUL\|GNE\|GNPTAB\|GNPTG\|GNS\|GOSR2\|GPC3\|GPHN\|GPR56\|GPR98\|GRIA3\|GRIN1\|GRIN2A\|GRIN2B\|GUSB\|HERC2\|HEXA\|HEXB\|HGSNAT\|HPD\|HRAS\|HSD17B10\|HSD17B4\|HYAL1\|IDS\|IDUA\|INPP5E\|IQSEC2\|KAT6B\|KCNA1\|KCNJ10\|KCNJ11\|KCNMA1\|KCNQ2\|KCNQ3\|KCNT1\|KCTD7\|KDM5C\|KIAA1279\|KMT2D\|KRAS\|L2HGDH\|LAMA2\|LARGE\|LBR\|LGI1\|LRPPRC\|MAGI2\|MAGT1\|MAP2K1\|MAP2K2\|MAPK10\|MBD5\|MCOLN1\|MCPH1\|ME2\|MECP2\|MED17\|MEF2C\|MFSD8\|MGAT2\|MGME1\|MLC1\|MMACHC\|MOCS1\|MOCS2\|MOGS\|MPDU1\|MPI\|MTHFR\|MTR\|MTRR\|NAGLU\|NDE1\|NDUFA1\|NDUFA2\|NDUFAF6\|NDUFS1\|NDUFS3\|NDUFS4\|NDUFS7\|NDUFS8\|NDUFV1\|NEU1\|NF1\|NHLRC1\|NIPBL\|NOTCH3\|NPC1\|NPC2\|NPHP1\|NRAS\|NRXN1\|OFD1\|OPHN1\|PAFAH1B1\|PAK3\|PANK2\|PAX6\|PC\|PCDH19\|PCNT\|PDHA1\|PDHX\|PDSS1\|PDSS2\|PEX1\|PEX10\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGK1\|PGM1\|PHF6\|PHGDH\|PIGV\|PLA2G6\|PLCB1\|PLP1\|PMM2\|PNKP\|PNPO\|POLG\|POMGNT1\|POMT1\|POMT2\|PPT1\|PQBP1\|PRICKLE1\|PRICKLE2\|PRODH\|PRRT2\|PSAP\|PSAT1\|PTCH1\|PTPN11\|QDPR\|RAB39B\|RAB3GAP1\|RAF1\|RAI1\|RARS2\|RBFOX1\|RELN\|RFT1\|RNASEH2A\|RNASEH2B\|RNASEH2C\|RPGRIP1L\|SAMHD1\|SCARB2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN8A\|SCN9A\|SCO2\|SDHA\|SERPINI1\|SETBP1\|SGSH\|SHH\|SHOC2\|SIX3\|SLC16A2\|SLC17A5\|SLC19A3\|SLC1A3\|SLC25A15\|SLC25A19\|SLC25A22\|SLC2A1\|SLC35A1\|SLC35A2\|SLC35C1\|SLC46A1\|SLC4A10\|SLC6A5\|SLC6A8\|SLC9A6\|SMC1A\|SMC3\|SMPD1\|SMS\|SNAP29\|SOS1\|SPRED1\|SPTAN1\|SRD5A3\|SRPX2\|STIL\|STXBP1\|SUCLA2\|SUMF1\|SUOX\|SURF1\|SYN1\|SYNGAP1\|SYP\|TACO1\|TBC1D24\|TBX1\|TCF4\|TGIF1\|TMEM165\|TMEM216\|TMEM67\|TMEM70\|TPP1\|TREX1\|TSC1\|TSC2\|TSEN2\|TSEN34\|TSEN54\|TUBA1A\|TUBA8\|TUBB2B\|TUSC3\|UBE3A\|VDAC1\|VPS13A\|VPS13B\|VRK1\|WDR62\|ZEB2\|ZIC2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Peripheral (whole) blood | Decline to answer | Yes
GTR000305767.1 | UW Cytogenetic Services University of Wisconsin - Madison/WSLH Wisconsin 52D0669558 305767 | 22q11.2 | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis | Fluorescence In Situ Hybridization\|Fluorescence In Situ Hybridization\|Microarray | Amniocytes\|Amniotic fluid\|Cord blood\|Fibroblasts\|Peripheral (whole) blood | Decline to answer | Yes

NR = Not reported

Table D-11 Genetic tests for Williams syndrome

GTR Test ID | Lab Name of Institution State CLIA Number Lab Test ID | Target Chromosomal Regions or Genes | Method Categories | Methods | Specimen Source | Genetic Counseling Required Pre-Test or Post-Test | Proficiency Testing Performed
GTR000019597.1 | Center for Human Genetics Laboratory University Hospitals - University Hospitals Laboratory Service Foundation Ohio 36D0656024 19597 | WBSCR | FISH-metaphase | Other | Amniocytes\|Amniotic fluid\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fetal blood\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000206883.1 | Center for Human Genetics, Inc Massachusetts 22D0650242 206883 | 7q11.23 | FISH-metaphase | Fluorescence in situ Hybridization (FISH) | Not reported | Decline to answer | No
GTR000295229.2 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 295229 | 7q11.23 | FISH-metaphase | Microduplication Metaphase FISH analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000295231.2 | Cincinnati Children’s Cytogenetics Laboratory Cincinnati Children’s Hospital Medical Center Ohio 36D0656333 295231 | 7q11.23 | FISH-metaphase | Microdeletion Metaphase FISH analysis | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Peripheral (whole) blood\|Product of conception (POC) | Decline to answer | Yes
GTR000500936.1 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 500936 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|C21orf33\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|G6PD\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|HTT\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000503671.2 | Courtagen Diagnostics Laboratory Courtagen Life Sciences Massachusetts 22D2035168 503671 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ACACA\|ACAD8\|ACAD9\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACO2\|ACSF3\|ACSL4\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AIFM1\|AK2\|AKAP10\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANKRD26\|APTX\|ARMS2\|ASS1\|ATIC\|ATP5E\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BCKDHA\|BCKDHB\|BCKDK\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDKL5\|CFTR\|CHAT\|CHRNA4\|CHRNB2\|CISD2\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|COA5\|COMT\|COQ2\|COQ6\|COQ9\|COX14\|COX15\|COX4I2\|COX6B1\|COX7B\|CPOX\|CPS1\|CPT1A\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDC\|DGUOK\|DHODH\|DHTKD1\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNM1L\|DTNBP1\|EARS2\|ELAC2\|ELN\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FARS2\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FXN\|G6PC\|GAD1\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLRA1\|GLRX5\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPD1\|GPD2\|GPI\|GPX1\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HAGH\|HARS\|HARS2\|HCCS\|HIBCH\|HK1\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B2\|HSPD1\|HTRA2\|IDH1\|IDH2\|IDH3B\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|L2HGDH\|LDHA\|LDHB\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MCCC1\|MCCC2\|MCEE\|ME2\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCS1\|MOCS2\|MOGS\|MPC1\|MPV17\|MRPL3\|MRPS16\|MRPS22\|MTFMT\|MTHFD1\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NCOA4\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB3\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NFU1\|NME1\|NNT\|NOS3\|NRXN1\|NT5C3A\|NUBPL\|OAT\|OGDH\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PAH\|PANK2\|PARK2\|PARK7\|PC\|PCBD1\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHYH\|PHYKPL\|PINK1\|PKLR\|PNKD\|PNMT\|PNPT1\|POLG\|POLG2\|PPARGC1B\|PPOX\|PPT1\|PRODH\|PTS\|PUS1\|PYCR1\|QDPR\|RARS2\|REEP1\|RMND1\|RNASEL\|RPL35A\|RPS14\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SOD1\|SOD2\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|SURF1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TP53\|TPH2\|TPP1\|TRMU\|TSFM\|TTC19\|TUFM\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS) | Cord blood\|Fresh tissue\|Frozen tissue\|Isolated DNA\|Peripheral (whole) blood\|Plasma\|Product of conception (POC)\|Saliva\|Serum\|Skin\|Urine\|White blood cell prep | Decline to answer | Yes
GTR000325588.1 | Cytogenetics and Molecular Genetics Laboratory Mercy St. Vincent Medical Center Ohio 36D0965797 325588 | 7q11.23 | FISH-metaphase | FISH | Peripheral (whole) blood | Decline to answer | Yes
GTR000509084.1 | Cytogenetics and Molecular Pathology Laboratory DLP Marquette General Hospital, LLC Michigan 23D1062707 509084 | ELN | FISH-interphase\|FISH-metaphase\|Karyotyping | FISH\|FISH\|G-banding | Buccal swab\|Cord blood\|Fetal blood\|Peripheral (whole) blood | No | Yes
GTR000013532.1 | Cytogenetics Laboratory Indiana University School of Medicine Indiana 15D0647198 13532 | 7q11.23 | FISH-interphase\|FISH-metaphase | Fluorescence in situ hybridization (FISH)\|Fluorescence in situ hybridization (FISH) | Amniocytes\|Amniotic fluid\|Bone marrow\|Chorionic villi\|Cord blood\|Cystic hygroma fluid\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin\|Urine | Decline to answer | Yes
GTR000032607.1 | Cytogenetics Laboratory SUNY Upstate Medical University New York 33D0654590 32607 | 7q11.23 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Cord blood\|Fetal blood\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Yes | Yes
GTR000500042.2 | Cytogenetics Laboratory ARUP Laboratories, Inc. Utah 46D0523979 500042 | 15q11.2-q13\|17p11.2\|17p13.3\|22q11.2\|22q13.3\|4p16.3\|5p15.2\|7q11.23\|Xp22.3\|Yp11.3 | FISH-metaphase | FISH-metaphase | Amniocytes\|Amniotic fluid\|Cell culture\|Chorionic villi\|Cord blood\|Fetal blood\|Fibroblasts\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | Decline to answer | Yes
GTR000501846.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501846 | 7q11.23 | FISH-metaphase | Fluorescence In Situ Hybridization | Cord blood\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood | No | No
GTR000501847.1 | Emory Genetics Laboratory Emory University School of Medicine Georgia 11D0683478 501847 | 7q11.23 | FISH-metaphase | Fluorescence In Situ Hybridization | Cell culture\|Fibroblasts | No | No
GTR000509372.9 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509372 | ABCC6\|ACTA2\|ACVR1\|ADAMTS2\|ATP6V0A2\|CBS\|CHST14\|COL11A1\|COL1A1\|COL1A2\|COL2A1\|COL3A1\|COL4A1\|COL5A1\|COL5A2\|ELN\|FBLN5\|FBN1\|FBN2\|FKBP14\|MYLK\|NOTCH1\|PKD2\|PLOD1\|PRDM5\|SLC2A10\|SLC39A13\|SMAD3\|TGFBR1\|TGFBR2\|ZNF469 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509394.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509394 | EFEMP2\|ELN\|FBLN5\|FLCN\|LTBP4\|SERPINA1\|TSC1\|TSC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000509435.8 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 509435 | ABCA3\|ACVRL1\|AP3B1\|ASCL1\|BDNF\|BLOC1S3\|BLOC1S6\|BMPR2\|CCDC39\|CCDC40\|CFTR\|DNAAF1\|DNAAF2\|DNAH11\|DNAH5\|DNAI1\|DNAI2\|DNAL1\|DTNBP1\|EDN3\|EFEMP2\|ELN\|ENG\|FBLN5\|FLCN\|GDNF\|HPS1\|HPS3\|HPS4\|HPS5\|HPS6\|LTBP4\|MUC5B\|NME8\|PHOX2B\|RET\|RSPH4A\|RSPH9\|SCNN1A\|SCNN1B\|SCNN1G\|SERPINA1\|SFTPA1\|SFTPA2\|SFTPB\|SFTPC\|SMAD9\|TERC\|TERT\|TSC1\|TSC2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000510915.7 | Fulgent Clinical Diagnostics Lab Fulgent Diagnostics California 05D2043189 510915 | AAAS\|AARS2\|AASS\|ABAT\|ABCB6\|ABCB7\|ABCC8\|ABCC9\|ABCD1\|ABCD3\|ACACA\|ACACB\|ACAD8\|ACAD9\|ACADL\|ACADM\|ACADS\|ACADSB\|ACADVL\|ACAT1\|ACAT2\|ACHE\|ACLY\|ACO2\|ACSF3\|ACSL4\|ACSL5\|ACSM3\|ADSL\|AFG3L2\|AGK\|AGPS\|AGXT\|AGXT2\|AIFM1\|AK2\|AKAP10\|AKR7A2\|AKT1\|AKT2\|ALAS2\|ALDH18A1\|ALDH2\|ALDH3A2\|ALDH4A1\|ALDH5A1\|ALDH6A1\|ALDH7A1\|AMACR\|AMT\|ANK2\|ANKRD26\|APTX\|ARMS2\|AS3MT\|ASS1\|ATIC\|ATP10D\|ATP5E\|ATP5SL\|ATP7B\|ATP8B1\|ATPAF2\|ATXN7\|AUH\|BAX\|BCAT1\|BCAT2\|BCKDHA\|BCKDHB\|BCL2\|BCS1L\|BOLA3\|C10orf2\|C12orf65\|CACNA1A\|CACNA1S\|CACNA2D1\|CASP8\|CDC42BPB\|CDKL5\|CFTR\|CHAT\|CHDH\|CHRNA4\|CHRNB2\|CISD2\|CKM\|CLCN1\|CLCN2\|CLCN5\|CLCN7\|CLCNKB\|CLN3\|CLN5\|CLN6\|CLN8\|CLYBL\|CNR1\|COA5\|COMT\|COQ2\|COQ4\|COQ5\|COQ6\|COQ9\|COX10\|COX15\|COX4I1\|COX4I2\|COX6B1\|COX7A2\|CPOX\|CPS1\|CPT1A\|CPT1B\|CPT2\|CTSD\|CYB5A\|CYB5R3\|CYBA\|CYBB\|CYCS\|CYP11A1\|CYP11B1\|CYP11B2\|CYP24A1\|CYP27A1\|CYP27B1\|D2HGDH\|DARS2\|DBT\|DDAH1\|DDC\|DECR1\|DGUOK\|DHODH\|DIABLO\|DISC1\|DLAT\|DLD\|DMGDH\|DMPK\|DNAJC19\|DNAJC5\|DNM1L\|DTNBP1\|EARS2\|ECI1\|ECSIT\|ELAC2\|ELN\|ENO1\|ENO3\|ETFA\|ETFB\|ETFDH\|ETHE1\|FAAH\|FARS2\|FASN\|FASTKD2\|FBP1\|FECH\|FH\|FOLR1\|FOXC1\|FOXG1\|FOXRED1\|FPGS\|FTH1\|FXN\|G6PC\|G6PD\|GAD1\|GAD2\|GALC\|GARS\|GATM\|GCDH\|GCK\|GCSH\|GDAP1\|GFER\|GFM1\|GK\|GLDC\|GLO1\|GLRA1\|GLRX5\|GLS\|GLUD1\|GLYCTK\|GNAS\|GNPAT\|GPAM\|GPD1\|GPD2\|GPI\|GPX1\|GPX4\|GYS1\|GYS2\|H6PD\|HADH\|HADHA\|HADHB\|HARS\|HARS2\|HCCS\|HIBCH\|HIGD2A\|HK1\|HK2\|HLCS\|HMGCL\|HMGCS2\|HOGA1\|HSD17B10\|HSD17B4\|HSD3B1\|HSD3B2\|HSPA9\|HSPB7\|HSPD1\|HTRA2\|HTT\|IDE\|IDH1\|IDH2\|IDH3B\|IMMP2L\|IMMT\|INSR\|ISCU\|IVD\|KARS\|KCNA1\|KCNE1\|KCNE2\|KCNH2\|KCNJ11\|KCNJ2\|KCNQ1\|KCNQ2\|KCNQ3\|KIF1B\|KRT5\|KYNU\|L2HGDH\|LARS2\|LDHA\|LDHB\|LETM1\|LIAS\|LRPPRC\|LRRK2\|MAOA\|MAOB\|MARS2\|MAVS\|MCCC1\|MCCC2\|MCEE\|MDH1\|MECP2\|MED23\|MEN1\|MFN2\|MFSD8\|MGLL\|MGST3\|MLYCD\|MMAA\|MMAB\|MMACHC\|MMADHC\|MOCOS\|MOCS1\|MOCS2\|MOGS\|MRPL3\|MRPL48\|MRPS16\|MRPS22\|MRRF\|MTCH2\|MTFMT\|MTHFD1\|MTHFD1L\|MTHFS\|MTO1\|MTPAP\|MTRR\|MUT\|MUTYH\|NAGS\|NARS2\|NDUFA1\|NDUFA10\|NDUFA11\|NDUFA12\|NDUFA13\|NDUFA2\|NDUFA4\|NDUFA6\|NDUFA7\|NDUFA8\|NDUFA9\|NDUFAF1\|NDUFAF2\|NDUFAF3\|NDUFAF4\|NDUFB1\|NDUFB3\|NDUFB6\|NDUFB9\|NDUFC2\|NDUFS1\|NDUFS2\|NDUFS3\|NDUFS4\|NDUFS5\|NDUFS6\|NDUFS7\|NDUFS8\|NDUFV1\|NDUFV2\|NDUFV3\|NFU1\|NIPSNAP1\|NIPSNAP3A\|NLRX1\|NME1\|NOS3\|NPL\|NRXN1\|NTHL1\|NUBPL\|OAT\|OGG1\|OPA1\|OPA3\|OTC\|OXCT1\|PACRG\|PAH\|PAK7\|PANK2\|PARK2\|PARL\|PARP1\|PC\|PCCA\|PCCB\|PCK1\|PCK2\|PDHA1\|PDHB\|PDHX\|PDP1\|PDSS1\|PDSS2\|PDX1\|PEX1\|PEX10\|PEX11B\|PEX12\|PEX13\|PEX14\|PEX16\|PEX19\|PEX2\|PEX26\|PEX3\|PEX5\|PEX6\|PEX7\|PGAM2\|PGK1\|PHB\|PHYH\|PKLR\|PMPCA\|PNKD\|PNMT\|POLG\|POLG2\|POLRMT\|PPARGC1A\|PPARGC1B\|PPOX\|PPT1\|PREPL\|PRODH\|PTGES2\|PTS\|PUS1\|PYCR1\|QDPR\|RAB11FIP5\|RARS2\|REEP1\|RNASEL\|RPL35A\|RRM2B\|RSPH9\|RYR1\|RYR2\|SACS\|SARDH\|SARS2\|SCN1A\|SCN1B\|SCN2A\|SCN4A\|SCN5A\|SCO1\|SCO2\|SCP2\|SDHA\|SDHAF1\|SDHAF2\|SDHB\|SDHC\|SDHD\|SECISBP2\|SHMT1\|SIRT1\|SIRT3\|SIRT5\|SLC16A1\|SLC19A2\|SLC22A4\|SLC22A5\|SLC25A12\|SLC25A13\|SLC25A15\|SLC25A19\|SLC25A20\|SLC25A22\|SLC25A3\|SLC25A38\|SLC25A39\|SLC25A4\|SLC27A4\|SLC2A1\|SLC3A1\|SLC6A8\|SPAST\|SPG20\|SPG7\|SPR\|SPTLC2\|STAR\|SUCLA2\|SUCLG1\|SUGCT\|SUOX\|TACO1\|TAP1\|TAT\|TAZ\|TCIRG1\|TDP1\|TFAM\|TFB1M\|TIMM44\|TIMM8A\|TK2\|TMEM126A\|TMEM70\|TOMM40\|TOP1MT\|TP53\|TPH2\|TPI1\|TPP1\|TRMU\|TSFM\|TSPO\|TST\|TTC19\|TUFM\|TXN2\|TXNRD2\|TYMP\|UBE3A\|UCP1\|UCP2\|UCP3\|UNG\|UQCRB\|UQCRQ\|UROS\|USP24\|WFS1\|WWOX\|XPNPEP3\|YARS2 | Deletion/duplication analysis\|Sequence analysis of the entire coding region | Next-Generation (NGS)/Massively parallel sequencing (MPS)\|Next-Generation (NGS)/Massively parallel sequencing (MPS) | Buccal swab\|Isolated DNA\|Peripheral (whole) blood\|Saliva | Decline to answer | No
GTR000053130.2 | Human Genetics Laboratory, Munroe-Meyer Institute University of Nebraska Medical Center Nebraska 28D0454363 53130 | 7q11.23 | FISH-interphase\|FISH-metaphase | Fluorescence in situ hybridization\|Fluorescence in situ hybridization | Fetal blood\|Peripheral (whole) blood | No | Yes
GTR000500654.2 | Michigan State University Clinical Genetics Laboratory Michigan State University Michigan 23D0650879 500654 | 7q11.23 | FISH-metaphase | Other | Amniocytes\|Bone marrow\|Cell culture\|Chorionic villi\|Fetal blood\|Fibroblasts\|Fresh tissue\|Peripheral (whole) blood\|Product of conception (POC)\|Skin | No | Yes
GTR000504365.1 | Quest Diagnostics Nichols Institute Chantilly Virginia 49D0221801 504365 | 7q11.23 | FISH-metaphase | Other | Peripheral (whole) blood | No | Yes
GTR000506049.2 | Quest Diagnostics Nichols Institute San Juan Capistrano California 05D0643352 506049 | 7q11.23 | FISH-metaphase | Other | Amniocytes\|Chorionic villi\|Peripheral (whole) blood | No | Yes
GTR000305785.1 | UW Cytogenetic Services University of Wisconsin - Madison/WSLH Wisconsin 52D0669558 305785 | 7q11.23 | FISH-interphase\|FISH-metaphase\|Deletion/duplication analysis | Fluorescence In Situ Hybridization\|Fluorescence In Situ Hybridization\|Microarray | Amniocytes\|Amniotic fluid\|Cord blood\|Fibroblasts\|Peripheral (whole) blood | Decline to answer | Yes