# Definition of Terms

The key terms used in this report are defined in this section. The definitions are from an Agency for Healthcare Research and Quality Evidence-based Practice Center method report we published, titled “Addressing Challenges in Genetic Test Evaluation. Evaluation Frameworks and Assessment of Analytic Validity.”34

Analytic accuracy: the closeness of agreement between the result of a measurement and a true value of the measurand.
Analytic sensitivity: the ability of a test to effectively detect all true-positive specimens, as determined by a reference method. As it is more often used, this term is used for tests that yield a qualitative result.
Analytic specificity: the ability of a measurement procedure to measure solely the analyte of interest. Two important aspects of analytic specificity are interference by endogenous or exogenous substances other than the analyte of interest and cross-reactivity of the analytic system with substances other than the intended analyte of interest.
Analytic validity: how well a test performs in the laboratory—how well does the test measure the properties or characteristic it is intended to measure (e.g., a gene mutation)?
Assay linearity: the ability (within a given range) to provide results that are directly proportional to the concentration (amount) of the analyte in the test sample. Linearity of tests is established by testing a dilution series of a positive sample.
Clinical utility: the usefulness of a test and the value of its information to medical practice. If a test has utility, it means that the results of the test can be used to seek effective treatment or provide other concrete benefit.
Clinical validity (also known as diagnostic accuracy): the accuracy with which a test predicts the presence or absence of a clinical condition or predisposition.
Cross-reactivity: the reaction that an assay may have with analytes other than the ones it is designed to measure.
Diagnostic accuracy: see clinical validity
Diagnostic sensitivity: the probability of a positive test result when disease is present.
Diagnostic specificity: the probability of a negative test result when disease is absent.
Gray literature: reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.
Health outcomes: symptoms and conditions that patients can feel or experience, such as visual impairment, pain, dyspnea, impaired functional status or quality of life, and death.
Interference: may result from contamination, admixture, or presence of exogenous substances in samples, which can occur for a variety of reasons such as poor sampling; lack of sample stabilizer (if appropriate); cross-contamination during sample processing, inclusion of normal, non-diseased tissue with the diseased tissue of interest, tissue from a source additional to the desired sample (e.g., maternal cells obtained during fetal specimen collection), or failure to remove exogenous substances (e.g., anticoagulants used during blood collection, residual reagents used during sample processing).
Intermediate outcomes: pathologic and physiologic measures that may precede or lead to health outcomes. For example, elevated blood cholesterol level is an intermediate outcome for coronary artery disease.
Precision: the closeness of agreement between independent results of measurements obtained under stipulated conditions. Precision is commonly determined by assessing repeatability and reproducibility (both of these terms are defined in this Appendix).
Recovery (as a term in the area of analytic validity): the measurable increase in analyte concentration or activity in a sample after adding a known amount of that analyte to the sample.
Reference range (also known as reference interval or normal values): the range of test values expected for a designated population of persons (e.g., 95 percent of people who are presumed to be healthy [or normal]).
Repeatability: replication of results when the assay is performed multiple times on a single specimen. Repeatability is also referred to as precision (in the term’s narrow sense) when the test result is expressed quantitatively.
Reportable range of test results: the span of test-result values over which the laboratory can establish or verify the accuracy of the instrument or test system measurement response.
Reproducibility: the closeness of agreement between independent results of measurements obtained with the same assay method when as many known variables as possible (e.g., operators, instruments, reagent lots, day of the week, sites/laboratories) are tested for their effect on the assay result.
Robustness: the ability of a method to remain unaffected by small fluctuations in assay parameters; it is often assessed through inter-laboratory comparison studies or by varying parameters such as temperature and relative humidity to determine the operating range of the method.
Traceability: a property of the result of a measurement or the value of a standard that relates to stated references, usually national or international standards, through an unbroken chain of comparisons, all having stated uncertainties.
Uncertainty: a parameter associated with the result of a measurement that characterizes the dispersion of the values that could reasonably be attributed to the measurand; it is a formal quantitative statement of the confidence in the result of an assay.