# Genetic Testing Overview

## DNA, Genes, and Development

DNA contains the information for constructing protein molecules that catalyze the cascade of biochemical reactions that govern the body’s growth and development as well as serving as some of the basic building blocks of cellular structure. The DNA in our cells is arranged as two helical strands of linearly-arranged chains of building blocks called nucleotides. There are four types of nucleotides in DNA: adenine (A), thymine (T), guanine (G), and cytosine (C). Due to the inherent chemical properties of these individual nucleotides, adenine and thymine have high affinities and attract one another (bond) when in proximity, as do cytosine and guanine. In a complete, double-stranded DNA molecule, each cytosine on one strand is aligned with a guanine on the other, and each adenine nucleotide on one strand is paired with a thymine on the other. As such, the two strands interlock, or hybridize, with each other. Further chemical interactions between individual nucleotides cause this entire assembly to adopt its unique helical shape.1,2

DNA is contained in chromosomes, complex structures located within the nucleus (central area) of cells. Chromosomes come in pairs, one from each parent. Humans have 23 pairs of chromosomes (46 chromosomes total) distinguished by their unique size and shape under a microscope. They are numbered from 1 to 22, with an additional, 23rd, pair of sex chromosomes, denoted X and Y. Girls have two X chromosomes (denoted XX), whereas boys have one X and one Y (denoted XY). Genes are segments of the DNA molecule that contain the information for constructing a particular protein (sequence of amino acids), dictated by their unique sequence of nucleotides. An allele is a particular form, or version, of a gene. Each individual typically has two alleles for each gene, with some exceptions.1,2

As stated above, DNA contains the information for the construction of protein molecules, linear chains of basic biochemical molecules called amino acids. Protein molecules are a part of the basic building blocks of cellular structure, and they facilitate metabolic reactions for the maintenance, growth, and proliferation of cells. The carefully-coordinated growth and proliferation of different types of specialized cells (e.g., brain, muscle, kidney cells) and the processes allowing for their coordinated function are responsible for organism development and growth.1 These processes are fundamentally dependent on activation of specific combinations of genes at the proper time, in much the same way that a well-played musical composition is dependent on the properly-timed activation of different musical notes.

## Genetic Disorders

Genetic disorders are medical conditions resulting from abnormalities in DNA (genes) or the regulatory processes that govern gene activation. Changes in the number or structure of chromosomes or aberrations in the total amount of DNA may cause or increase the risk of congenital defects, developmental delays, behavioral disorders, and intellectual disabilities. For instance, Down syndrome, also known as trisomy 21, is a disorder causing mental retardation. It is caused by the presence of three copies of all or part of the 21st chromosome (an example of an aneuploidy, a condition marked by an abnormal number of chromosomes in each cell).3 Other disorders, such as Rett syndrome, a developmental disorder associated with delayed development and intellectual disability, can result from a defect (or mutation) in a single gene.4 In many cases, however, developmental disorders are caused by multiple genetic mutations. Autism, intellectual disabilities, and developmental delay, for instance, are often due to a combination of abnormalities in a number of different genes.5 Typically, for these disorders, a given genetic abnormality may confer an increase in risk for the disorder but do not by themselves cause the disorder. Possessing a greater number of risk-conferring genetic abnormalities will increase one’s chances of having a disorder. Copy-number variations (CNVs) are another example of structural variation that can increase the risk of disease. CNVs are relatively large portions of the genome that have been deleted or duplicated on certain chromosomes, resulting in the cells having, respectively, fewer or more copies of certain segments of DNA. The role of CNVs in conferring risk for developmental disorders is a very active area of research.6

Understanding the tremendous heterogeneity in genetic makeup that can predispose individuals to disease is a major scientific hurdle that must be surmounted in order to develop more effective treatments, and potentially cures, for developmental disorders. Efforts to advance the field of genetic testing have focused on meeting this challenge.

## Genetic Testing

Identifying the aberrations in genetic material that underlie disease states is a central task in better understanding disease etiology and for developing more effective treatments. Many different types of genetic tests exist that can reveal abnormalities in genetic information at varying levels of complexity, ranging from the gain or absence of entire chromosomes to mutations in a single nucleotide within a gene.

Cytogenetic testing (or chromosome testing) examines the number and structure of chromosomes. This type of testing can detect whether there are too many or too few of any one chromosome, or whether there is too much (gain) or too little (loss) of a particular portion of the chromosomes. Disorders such as Down syndrome (discussed above) and fragile X syndrome (mental retardation due to abnormalities of the X chromosome) are consequences of such abnormalities.

Karyotyping is a test involving the gross examination of chromosomes in a sample of cells. Karyotyping can reveal variations in the number of chromosomes (as in Down syndrome) and large-scale structural abnormalities in individual chromosomes. Chromosome banding methods are an extension of karyotyping. When treated with various dyes, different segments along the length of a chromosome stain to different degrees. This produces a banding pattern, like a series of stripes, perpendicular to the long axis of the chromosome. This banding pattern can be viewed under a microscope and provides a more detailed image of chromosome microstructure, making possible the identification of smaller-scale chromosomal abnormalities such as translocations (relocations of DNA segments from one chromosome to another), missing segments of DNA (deletions), and amplifications (multiple copies of chromosomal segments).2,7

An increasingly sophisticated panoply of tools from molecular biology has greatly enhanced the level of detail and rapidity with which genetic abnormalities can be detected and analyzed. These molecular-based genetic tests are the primary subjects of this report and we provide a brief survey of these below.

Fluorescence in situ hybridization (FISH) allows for visualization and mapping of specific genes or portions of genes. It can be used to identify where a particular gene falls within an individual’s chromosomes. This is accomplished by preparing short sequences of single-stranded DNA (called probes) that are complimentary (in their nucleotide sequence) to the gene or portions of the gene of interest. These probes are then labeled by attaching one of a number of fluorescent dyes of a specific color. Because the probes are single-stranded, they can bind to complementary strands of DNA in the person’s chromosomes, thus visually “tagging” the gene or gene segment of interest.1,8

## Advanced Genetic Tests

In the past 10–15 years, genetic testing methods have greatly increased in sophistication. It is now possible not only to examine abnormalities in the number or structure of individual chromosomes, but also to examine the composition of large portions of the genome or even its entirety. Today, four major genome-wide assays are used to assess single nucleotide polymorphism (SNP) base variants and CNVs, ordered in terms of method sophistication and clinical utility:

- Array comparative genomic hybridization (aCGH)
- SNP microarray (array)
- Whole exome sequencing (WES)
- Whole genome sequencing (WGS)

Array CGH is a more recent genetic testing technology that allows the detection of very small chromosomal imbalances that cannot be identified through karyotyping (analysis of gross structure with use of a microscope). Very small changes in the amount of genetic information are referred to as microduplications (gain of genetic information) or microdeletions (loss of genetic information). Array CGH compares an individual’s DNA with a control sample of DNA (typically from an individual not possessing the disorder of interest) and identifies differences between the two sets of DNA. Array CGH efficiently identifies deletions or duplications (imbalances) in an individual’s DNA. This allows physicians and researchers to relate an individual’s physical and mental characteristics (phenotype) to detailed profile of their genetic makeup (genotype).9,10

Because of the binding properties of DNA nucleotide base pairs, one strand of DNA will bind to (or “hybridize”) with another strand having complimentary nucleotide sequence. This property forms the basis of the aCGH technique. A DNA microarray is comprised of thousands of short sequences of DNA, called “probes,” arranged in a precise spatial grid on the surface of a glass slide, termed a DNA “chip.” DNA from a patient is first “digested” with bacterial restriction enzymes that chop it up into short fragments (restriction enzymes are an evolutionary adaptation by bacteria to combat viral infection). These fragments are labeled with a fluorescent dye of a specific color. Reference DNA from another subject or multiple subjects with no known genetic abnormalities is also digested and labeled with fluorescent dye of another color (often, red and green dyes are used for the patient and control subjects, respectively). The two DNA samples, one from the patient and the other from the normal individual or group, are mixed together and applied to the surface of the chip. The applied fragments of DNA then hybridize with their complimentary probes, thus fluorescently labeling the spatial locations on the DNA chip containing the complimentary nucleotide sequences. The DNA chip and attached DNA test fragments can then be “read” by a microarray scanner which calculates the ratio of red and green fluorescence emitted from each location on the chip. Locations on the chip (representing specific segments of the DNA molecule) that have an equivalent degree of complimentary binding to the two patient samples will fluoresce yellow, indicating the patient has the same amount of genetic material as the control subjects in this segment of DNA. If the patient has a deletion at that segment, there will be more green fluorescence, while a duplication will result in more red fluorescence. Array CGH readings are quantified in terms of intensity data (of one color) alone (normalized at 0 for diploid), and so typically are used to determine duplications and deletions.9–11

Single nucleotide polymorphism microarrays (SNPs, or “snips”) are genome positions where two distinct nucleotide residues exist on different alleles, with each one appearing in a substantial portion of the human population. SNPs comprise a major portion of human genetic variability, with an estimate of 10 million SNPs in the human genome. SNP arrays are useful for identifying small variations between whole genomes. SNP arrays work on the same general principles as aCGH, but while DNA from both a patient and control subjects are used in aCGH, SNP arrays involve hybridization of only the patient’s DNA. SNP arrays utilize two different oligonucleotides, one matching each of two variant alleles. The two alleles of a SNP are typically denoted A and B, and because each individual usually inherits one allele from each parent, the individual’s genotype at a given SNP site will be AA, AB or BB. SNP arrays, therefore, can tell whether specific genetic variants are present and also provide the specific genotype of these variants with fluorescent intensity data (normalized at 0, 0.5 and 1 for AA, AB, and BB, respectively), throughout the entire genome.12,13

Originally, SNP arrays were designed for genome-wide association studies, being used to detect genotypes for thousands of single-nucleotide differences (polymorphisms) across an entire genome. More recent applications for SNP arrays include determining disease risk (similar to aCGH) and predicting or measuring the efficacy of drug therapies for individual patients. SNP arrays can also detect uniparental disomy (receiving two copies of a chromosome from one parent), consanguinity (offspring resulting from matings of close relatives), and copy number variation (CNVs).12–14

Whole-exome and whole-genome sequencing. DNA contains both coding regions (portions of the DNA that code for proteins, termed exons) and non-coding regions (termed introns). The entirety of the protein-coding regions of all DNA in a genome (all of the exons) is termed the “exome.” The entirety of human DNA contains roughly 180,000 exons that comprise roughly 1% of the entire genome. These 180,000 exons are distributed throughout about 22,000 genes. Since exons code for proteins, they contain most of the errors that occur in DNA sequences that underlie genetic disorders.15–17 Exome sequencing is therefore an efficient method of analyzing a patient’s DNA to elucidate the underlying cause of many diseases and disabilities. WES uses genome-wide, targeted exon capture to define the precise sequence of individual nucleotides in the entire exome, called the “consensus sequence.” This consensus sequence is then compared to standard and reference sequences representing what is normal (or genetically typical) of the overall population. Variations in an individual’s DNA sequence relative to standards can then be identified to help assess the risk of disease or be used along with a patient’s clinical assessment to either confirm or help establish a diagnosis. WES is of primary importance for identifying and analyzing base and copy variants, alike. Additionally, WES also examines DNA found within mitochondria, small structures within a cell that participate in providing usable energy for the body.18–20

WGS is a method for resolving the detailed nucleotide sequence of the entire genome. (Although the whole genome, or exome for WES, is theoretically sequenced, some regions are poorly sequenced or mapped to the genome, creating residual variability and imperfect continuous coverage.) WGS, therefore, has the ultimate potential to resolve almost the entirety of structural variation in a patient’s genome, including intronic as well as exonic segments of DNA. Although introns do not code directly for proteins, they may affect the extraction of information from DNA in exonic regions and may have other regulatory functions on genetic networks.21 Examining sequence variations in these regions has the potential to reveal additional contributors to disease. Even in otherwise healthy individuals, WES and WGS are expected to reveal genetic variations of potential clinical importance. Many clinicians have already acknowledged the potential of WES and WGS to aid clinical diagnosis, identify the genetic underpinnings of rare diseases, and help inform studies in the biological basis of disease.22–24

Polymerase chain reaction (PCR) is a biochemical method for replicating strands of DNA. Beginning with a few strands of DNA, PCR can be used to generate thousands or millions of new copies in a relatively short time.2,25 PCR makes use of DNA polymerases, a class of enzymes that operate within cells to create new DNA. DNA replication normally occurs when cells divide in a fashion that maintains the total complement of genetic material in each resulting cell constant. Once two strands of a DNA molecule are separated, a given molecule of DNA polymerase can attach to one of the strands and begin catalyzing the addition of complimentary nucleotides to that strand to once again form a complete segment of double-stranded DNA.2,25 By exposing segments of DNA repeatedly to cycles of heating followed by cooling (thermal cycling) in the presence of DNA polymerase and short segments of complimentary DNA called primers, this process of DNA replication can be repeated many times over (usually 25–40 times), creating an exponential increase in the number of DNA strands. These thermal cycles normally consist of three stages: the first stage, carried out at about 95–98 °C, causes separation of the two strands of DNA. In the second stage, at a temperature of about 50–60 °C, the primers bind to the DNA template. Finally, the third stage, carried out at about 72 °C, facilitates the polymerization carried out by the DNA polymerase. PCR is indispensable in isolating and amplifying DNA segments for research purposes, as well as aiding in the diagnosis of genetic disorders, DNA fingerprinting, and detecting and identifying viruses or bacteria.2,26

Multiplex-PCR is a variation of the PCR technique that employs multiple primer sets within a single PCR mixture, producing different amplicons (a segment of replicated DNA or RNA) of varying sizes, each specific to a unique DNA sequence. Using PCR to target multiple genes at once provides additional information from a single test run that otherwise would require considerably more time and resources to perform.27

Quantitative PCR (qPCR) uses the PCR technique to amplify and quantify a specific DNA segment. Amplified DNA is detected during the PCR reaction in “real time.” To detect products of qPCR reactions, fluorescent dyes that embed into double-stranded DNA or fluorescently labeled oligonucleotides (short, artificially-created segments of DNA) that activate upon binding a complementary sequence are commonly used. Quantitative PCR is carried out in a thermal cycler with the capacity to quantify the amount of fluorescence and thus the presence and amount of each type of DNA produced.28,29

Multiplex ligation-dependent probe amplification (MLPA) is a special instance of multiplex PCR. It can be used to detect small copy-number changes in DNA or RNA sequences, such as deletions or duplications within a single gene and is more sensitive than real-time PCR. Unlike multiplex PCR, MLPA allows for the detection of aberrant copy number in many genomic DNA sequences in a single PCR reaction. It can also detect methylation status of DNA segments. Methylation is a process by which certain genes can be inactivated within a cell (see discussion below). MLPA requires very little DNA and can discriminate sequences differing in only a single nucleotide. For laboratory purposes, it has the added advantage of being applicable to partially degraded DNA, as might be found in chemically-treated or preserved tissue samples.30,31

The MLPA process begins with an MLPA probe that contains two probe oligonucleotides, short segments of manufactured DNA complimentary to a sequence of interest in a sample of DNA. If the probe’s target sequence is present in the sample DNA, the two probe oligonucleotides attach to the sample next to each other and are ligated (connected together). The ligated probes (not the sample DNA) are then amplified in the multiplex PCR reaction. The relative amounts of amplification products generated by the probes then reflect the relative copy number (copy number variation) of target sequences.30,31

MLPA is a very fast and accurate way to detect genomic CNVs, deletions and insertions that are frequent contributors to disorders such as autism and Prader-Willi or Angelman syndromes. MLPA can easily discriminate the relative copy number of all exons within a gene simultaneously with high sensitivity.30,31

DNA methylation analysis is a biochemical process in which a methyl group is added to the cytosine or adenine DNA nucleotides causing the DNA sequence to be inaccessible to enzymes involved in transcribing information to form proteins. Methylation, therefore, essentially “locks” the gene in the off position. DNA methylation plays an important role in organism development and in the genesis of disease, acting as a major influence in epigenetic gene regulation (the activation and deactivation of subsets of the genome, oftentimes in response to environmental influences). Different diseases are associated with different methylation patterns across many genes. In developmental disorders, these patterns of gene regulation exert powerful influences over the developing organism. Identifying methylation patterns, or “signatures,” throughout the genome can, in principle, provide a very powerful diagnostic tool. DNA methylation is detected by a variety of assays currently used in scientific research, including mass spectrometry, methylation-specific PCR, and whole genome bisulfite sequencing.32,33