# Literature Search Methods

## Resources Searched

ECRI Institute information specialists searched the following databases for relevant information. Search terms and strategies for each resource appear below.

Name | Date Limits | Platform/Provider
Bibliographic Databases
The Cochrane Central Register of Controlled Trials (CENTRAL) | 2009 through August 27, 2014 | Wiley
The Cochrane Database of Methodology Reviews (Methodology Reviews) | 2009 through August 27, 2014 | Wiley
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | 2009 through August 27, 2014 | Wiley
Database of Abstracts of Reviews of Effects (DARE) | 2009 through August 27, 2014 | Wiley
EMBASE (Excerpta Medica) | 2009 through August 12, 2014 | Embase.com
Health Technology Assessment Database (HTA) | 2009 through August 27, 2014 | Wiley
MEDLINE | 2009 through August 12, 2014 | Embase.com
PUBMED (PreMEDLINE) | Searched August 13, 2014 | NLM
U.K. National Health Service Economic Evaluation Database (NHS EED) | 2009 through August 27, 2014 | Wiley
Gray Literature Resources
American College of Medical Genetics and Genomics | | ACMG
American Society of Human Genetics | | ASHG
ClinicalTrials.gov | Searched August 26, 2014 | NLM
EuroGentest – Clinical Utility Gene Cards | Searched August 28, 2014 | Center for Human Genetics – University of Leuven
Genetic Test Registry | Searched throughout project | NCBI
Internet | Searched August 28, 2014 | Google
MedGen | Searched March 7, 2014 | NCBI
National Guideline Clearinghouse™ (NGC) | Searched August 27, 2014 | AHRQ

## Hand Searches of Journal and Gray Literature

Journals and supplements maintained in ECRI Institute’s collections were reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

## Topic-Specific Search Terms

The search strategies employed combinations of free-text keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. Strategies for each bibliographic database follow this table.

### Medical subject headings (MeSH), EMTREE, and keywords

Concept | Controlled Vocabulary | Keywords
Conditions | MEDLINE (MeSH) ‘Child development disorders, pervasive’/exp ‘Chromosome disorders’/exp ‘Developmental disabilities’/exp ‘Intellectual disabilities’/exp EMBASE (EMTREE) ‘autism’/exp ‘cognitive defect’:de ‘congenital disorder’:lnk ‘intellectual impairment’:de ‘mental deficiency’/exp ‘mental retardation malformation syndrome’/exp ‘postnatal development’/exp | Autism Autistic ASD Asperger* PDD near/1 NOS PDDNOS Pervasive developmental disorder* Rett syndrome Developmental delay Developmental disability Intellectual delay Intellectual disability Mental retardation Neurocognitive impairment 1p36 deletion syndrome 9q deletion syndrome 17q21.31 deletion syndrome 18p minus syndrome 18q minus syndrome Alagille syndrome Angelman syndrome Charcot-Marie-Toothe syndrome Conotruncal anomaly face syndrome Cri du Chat syndrome DiGeorge syndrome Down syndrome Fragile x Fragile-x Happy puppet syndrome Jacobsen syndrome Kleefstra syndrome Koolen-de-vries syndrome Langer Gideon syndrome Miller-Dieker syndrome Prader-Willi PTEN deletion Rubinstein-Taybi Shrprintzen syndrome Smith-Magenis SRY deletion Velocardiofacial syndrome Wagr syndrome Williams syndrome Williams-Beuren syndrome Wolf-Hirschorn syndrome
Genetic Testing | MEDLINE (MeSH) ‘chromosome disorders’/exp ‘genetic techniques’/exp ‘genetic testing’/exp ‘microarray analysis’/exp ‘oligonucleotide array sequence analysis’:de ‘comparative genomic hybridization’:de ‘molecular sequence data’ ‘sequence analysis, DNA’:de ‘sequence deletion’/genetics EMBASE (EMTREE) ‘chromosome aberration’/exp – note- this is a large category that encompasses the entire scope of this report. ‘epigenetics’:de ‘exome’:de ‘gene mutation’/exp ‘gene sequencing’:de ‘genetic screening’:de ‘genetic procedures’/exp ‘genome’:de ‘genome imprinting’:de ‘microarray analysis’:de ‘molecular diagnosis’:de ‘nucleic acid analysis’/exp | aCGH Array CGH Array genomic hybridization cDNA array cDNA microarray Chromosomal microarray analysis Chromosome deletion Chromosome duplication Comparative genomic hybridization Copy number Epigenetic* Gene chip* Genetic test* Imprinting Methylation Molecular diagnosis Next generation sequencing Nexgen NGS Single nucleotide polymorphism array SNP Whole exome Whole genome Affymetrix Agilent Technologies CytoScan Nimblegen Illumina
Specific genes and deletions | | Copy number variants CNV CDKL5 CREBBP EP300 FMR1 FMR-1 FOXG1 MECP2 TSC1 TSC2 UBE3A 10p deletion 20p deletion Deletion 1p36 Deletion 7q11.23 Deletion 10q13-q14 Deletion 17p11.2 Deletion 22q11.2 GJB6 deletion IDIC15 duplication Maternal deletion 15q11-q13 Paternal deletion 15q11-q13 STRC deletion

## Search Strategies

### EMBASE/MEDLINE (presented in Embase.com syntax)

Set Number | Concept | Search Statement
1 | Genetic testing | ‘Chromosome aberration’/exp or (chromosom* NEAR/2 (duplicat* or deletion or ‘copy number’ or insertion))
2 | Genetic testing | ‘microarray analysis’:de or ‘nucleic acid analysis’/exp or ‘molecular diagnosis’:de or ‘genetic screening’:de or ‘genetic procedures’/exp or ‘array cgh’ or ‘aCGH’ or ‘CMA’ or ‘comparative genomic hybridization’ or ‘array genomic hybridization’ or microarray or (molecular NEAR/2 diagnos*) or snp or ‘single nucleotide polymorphism array’ or (genetic NEAR/2 test*)
3 | Genetic testing | (exome:de OR genome:de) and ‘gene sequencing’:de
4 | Genetic testing | (‘whole exome’ or ‘whole genome’) NEAR/3 sequencing
5 | Genetic testing | ‘next generation sequencing’ or ‘NGS’
6 | Genetic testing | ‘gene expression assay’/exp or ‘gene chips’ or ‘cDNA array’ or ‘cDNA microarray’ or ‘genome imprinting’:de or imprinting
7 | Genetic testing | Methylation or ‘epigenetics’:de or epigenetic*
8 | Genetic testing | #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7
9 | Conditions | Development* NEAR/2 (delay* or disabilit*)
10 | Conditions | ‘mental deficiency’/exp or (mental* NEAR/2 retard*) or (intellect* NEAR/2 (disabilit* or delay*))
11 | Conditions | (Neurocognitive NEAR/2 impair*) or ‘cognitive defect’:de or ‘intellectual impairment’:de
12 | Conditions | ‘Fragile X’ or ‘fragile-x’ or ‘mental retardation malformation syndrome’/exp
13 | Conditions | ‘autism’/exp or autistic* or autism or Asperger*:ti,ab or ‘asd’:ti,ab or ‘rett syndrome’ or ‘pervasive developmental disorder’ or ‘PDD’
14 | Specific syndromes (original) | ‘angelman syndrome’/exp OR ‘happy puppet’ OR ‘prader-willi’/exp OR ‘rubinstein-taybi’/exp OR ‘smith magenis’/exp OR ‘velocardiofacial syndrome’/exp OR ‘digeorge syndrome’/exp OR ‘shrprintzen syndrome’ OR ‘conotruncal anomaly face syndrome’ OR ‘williams syndrome’/exp OR ‘williams-beuren syndrome’/exp
15 | Specific syndromes – KI suggested | ‘kleefstra syndrome’ OR ‘miller-dieker syndrome’ OR ‘koolen-de vries syndomre’ OR ‘wagr syndrome’ OR ‘langer gideon syndrome’ OR ‘cri du chat syndrome’ OR ‘wolf-hirschorn syndrome’ OR ‘jacobsen syndrome’ OR ‘alagille syndrome’ OR ‘1p36 deletion syndrome’ OR ‘9q deletion syndrome’ OR ‘17q21.31 deletion syndrome’ OR ‘18p minus syndrome’ OR ‘18q minus syndrome’ OR ‘sry deletion’ OR ‘pten deletion’ OR ‘charcot-marie-toothe syndrome’
16 | Specific genes | ube3a OR fmr1 OR mecp2 OR cdkl5 OR foxg1 OR crebbp OR ep300
17 | Combine sets | #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16
18 | Removing rodents | #17 NOT (mouse*:ti OR mice:ti OR murine:ti OR rat:ti OR rodent:ti)
19 | Diagnosis | ‘diagnostic test accuracy’:de OR ‘diagnosis’:lnk OR ‘receiver operating characteristic’:de OR ‘roc curve’/exp OR ‘roc curve’ OR ‘sensitivity and specificity’:de OR ‘sensitivity’ OR ‘specficity’ OR ‘accuracy’:de OR ‘precision’/exp OR precision OR ‘prediction and forecasting’/exp OR ‘prediction and forecasting’ OR ‘diagnostic error’/exp OR ‘diagnostic error’ OR ‘maximum likelihood method’:de OR ‘likelihood’ OR ‘predictive value’/exp OR ‘predictive value’ OR ppv OR (false OR true) NEAR/1 (positive OR negative)
20 | Combine sets | #18 AND #19
21 | Limit by keywords | #18 AND (idiopathic or (clinical NEAR/2 (valid* or util* or relevanc*)))
22 | Combine sets | #20 OR #21
23 | Limits | #22 NOT (prenatal:ti or maternal:ti)
24 | Limit by publication and study type | #23 AND (‘clinical article’/de OR ‘clinical trial’/de OR ‘cohort analysis’/de OR ‘comparative study’/de OR ‘controlled study’/de OR ‘diagnostic test accuracy study’/de OR ‘intermethod comparison’/de OR ‘major clinical study’/de OR ‘medical record review’/de OR ‘practice guideline’/de OR ‘prospective study’/de OR ‘retrospective study’/de OR ‘validation study’/de) AND (‘Article’/it OR ‘Article in Press’/it OR ‘Conference Abstract’/it OR ‘Conference Paper’/it OR ‘Review’/it)

#### EMBASE.com Syntax

* | = truncation character (wildcard)
NEAR/n | = search terms within a specified number (n) of words from each other in any order
NEXT/n | = search terms within a specified number (n) of words from each other in the order specified
/ | = search as a subject heading
exp | = “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary’s hierarchy)
mj | = denotes a term that has been searched as a major subject heading
:de | = search in the descriptors field
:lnk | = floating subheading
:it,pt. | = source item or publication type
:ti. | = limit to title
:ti,ab. | = limit to title and abstract fields

### PUBMED (PreMEDLINE)

Strategy: limits = human, English language

Set Number | Concept | Search Statement
1 | Genetic testing | Chromosom* AND (aberration* OR duplicat* OR deletion* OR “copy number repeat” OR insertion*)
2 | Genetic testing | Microarray* OR “nucleic acid analysis” OR “molecular diagnosis” OR “molecular testing” OR “genetic screening” OR “array CGH” OR “aCGH” OR “CMA” OR “comparative genomic hybridization” OR “array genomic hybridization” OR “single nucleotide polymorphism array”
3 | Genetic testing | “whole genome sequencing” OR “whole exome sequencing”
4 | Genetic testing | “next generation sequencing” OR “NGS”
5 | Genetic testing | “gene expression assay” OR “gene chips” OR “cDNA array” OR “cDNA microarray” OR “genome imprinting” OR imprinting
6 | Genetic testing | Methylation OR epigenetic*
7 | Genetic testing | #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7
8 | Conditions | “developmental delay” OR “developmental deficiency”
9 | Conditions | “mental deficiency” OR “mental retardation” OR “mentally retarded” OR “intellectual disability” OR “intellectual delay” OR “intellectual impairment”
10 | Conditions | “neurocognitive impairment” OR “cognitive defect”
11 | Conditions | “Fragile X” OR “fragile-x”
12 | Conditions | autistic* OR autism OR Asperger*[tiab] OR ‘asd’ OR “rett syndrome” OR “pervasive developmental disorder” OR PDD
13 | Conditions | “angelman syndrome” OR “happy puppet” OR “prader-willi” OR “rubinstein-taybi” OR “smith Magenis” OR “velocardiofacial syndrome” OR “digeorge syndrome” OR “shrprintzen syndrome” OR “conotruncal anomaly face syndrome” OR “williams syndrome” OR “williams-beuren syndrome”
14 | Conditions | “kleefstra syndrome” OR “miller-dieker syndrome” OR “koolen-de vries syndome” OR “wagr syndrome” OR “langer gideon syndrome” OR “cri du chat syndrome” OR “wolf-hirschorn syndrome” OR “jacobsen syndrome” OR “alagille syndrome” OR “1p36 deletion syndrome” OR “9q deletion syndrome” OR “17q21.31 deletion syndrome” OR “18p minus syndrome” OR “18q minus syndrome” OR “sry deletion” OR “pten deletion” OR “charcot-marie-toothe syndrome”
14 | Conditions | ube3a OR fmr1 OR mecp2 OR cdkl5 OR foxg1 OR crebbp OR ep300
16 | Combine sets | #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 #7 AND #16
17 | Limit to in process | #16 AND (pubmednotmedline[sb] OR inprocess[sb] OR [publisher[sb])
18 | Diagnosis | #17 AND (diagnos* OR detect* OR identif* OR “clinical validity” OR “clinical utility” OR “clinical relevancy”)
19 | Diagnosis | #17 AND idiopathic
20 | Diagnosis | #18 OR #19
21 | Diagnosis | #20 AND English[la]
22 | Diagnosis | #21 NOT (prenatal OR fetal OR maternal)
23 | Diagnosis | #22 NOT (cancer* OR neoplasm* OR tumor* OR tumour* OR carcinoma* OR sarcoma* OR glioma*)
24 | Diagnosis | #23 AND (rat OR rats OR rodent* OR mouse OR mice OR murine OR hamster*)
25 | Diagnosis | #23 NOT #24

#### PubMed Syntax

* | = truncation character (wildcard)
[ti] | = limit to title field
[tiab] | = limit to title and abstract fields
[tw] | = text word

### Cochrane Library databases

Search Strategy | Search Statement | Number Identified
#1 | MeSH descriptor: [Chromosome Disorders] explode all trees | 645
#2 | chromosom* near/2 (duplicat* or deletion or ‘copy number’ or insertion) | 80
#3 | MeSH descriptor: [Microarray Analysis] explode all trees | 269
#4 | MeSH descriptor: [Genetic Techniques] explode all trees | 4,696
#5 | MeSH descriptor: [Genetic Testing] explode all trees | 494
#6 | ‘array cgh’ or ‘aCGH’ or ‘CMA’ or ‘comparative genomic hybridization’ or ‘array genomic hybridization’ or microarray or (molecular near/2 diagnos*) or snp or ‘single nucleotide’ | 2,543
#7 | (‘whole exome’ or ‘whole genome’) near/3 sequencing | 13
#8 | ‘next generation sequencing’ or ‘NGS’ | 2,158
#9 | ‘gene chips’ or ‘cDNA array’ or ‘cDNA microarray’ | 72
#10 | Methylation or epigenetic* | 358
#11 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 | 9,411
#12 | Development* near/2 (delay* or disabilit*) | 1,404
#13 | (mental* near/2 retard*) or (intellect* near/2 (disabilit* or delay*)) | 1,643
#14 | MeSH descriptor: [Developmental Disabilities] explode all trees | 453
#15 | MeSH descriptor: [Intellectual Disability] explode all trees | 1,020
#16 | (Neurocognitive near/2 impair*) | 83
#17 | “happy puppet” or “conotruncal anomaly face syndrome” or “kleefstra syndrome” or “miller-dieker syndrome” or “koolen-de vries syndrome” or “WAGR syndrome” or “langer Gideon syndrome” or “cri du chat syndrome” or “alagille syndrome” or “1p36 deletion syndrome” or “9g deletion syndrome” or “17q21.31 deletion syndrome” or “18p minus syndrome” or “18q minus syndrome” or “sry deletion” or “pten deletion” or “characote-marie-toothe syndrome” | 10
#18 | ube3a or FMR1 or mecp2 or cdkl5 or foxg1 or crebbp or ep300 | 25
#19 | “fragile x” or “fragile-x” | 73
#20 | MeSH descriptor: [Autistic Disorder] explode all trees | 519
#21 | MeSH descriptor: [Asperger Syndrome] explode all trees | 39
#22 | Autism or autistic | 1,154
#23 | #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 | 4,149
#24 | #11 and #23 Publication Year from 2009 to 2014 | 306
#25 | #24 and (diagnos* or “receiver operating characteristic” or “ROC” or sensitivity or specificity or accuracy or precision or prediction or predictive) | 227
#26 | #24 and ((true or false) near/1 (positive or negative)) | 31
#27 | #24 and idiopathic | 12
#28 | #24 and (clinical near/2 (valid* or util* or relevanc*)) | 19
#29 | #25 or #26 or #27 or #28 | 228

#### Cochrane Library Syntax

* | = truncation character (wildcard)

The Cochrane Library via the Wiley platform is menu-driven.