# Summary and Implications

A wide variety of studies have been published examining strategies for environmental cleaning (EC,) including 47 studies of surface cleaning/disinfection modalities, 12 studies of strategies for monitoring cleanliness, and 17 studies addressing implementation of best practices. Many surface disinfection techniques were evaluated, including well-established products such as quaternary ammonium and bleach, recently emerging technologies such as UV-C light, hydrogen peroxide vapor, and copper coatings, and less frequently used approaches, including sporicidal wipes and microfiber cleaning instruments. Multiple studies assessed several different monitoring techniques, including ATP, UV light, microbiologic colony counts, and visual inspection. Analyses of implementation studies demonstrated that numerous factors, such as culture, leadership, use of process standardization and feedback to staff, and organizational structure, can serve as facilitators or barriers to improving EVS practices. Challenges were also highlighted, including regulatory requirements, use of outsourcing to provide cleaning services, and sustaining improvement over time.

## Cleaning and Disinfection Modalities

Surface cleaning and disinfection products and technologies have been widely studied, but the evidence base and current expert opinion have yielded consensus favoring only the value of quaternary ammonium and chlorine-based products. These chemical agents are the primary disinfectants used for routine disinfection of hospital rooms, with hypochlorites often recommended for rooms of patients infected with C. difficile. Use of wipes soaked in peracetic acid or hydrogen peroxide may be an alternative to QAC and bleach for manual surface disinfection, but studies supporting their effectiveness have only recently emerged.

Augmentation of manual surface cleaning and disinfection with automated disinfection technologies has been examined increasingly in recent years. Nine studies of UV light and seven studies of hydrogen peroxide vapor machines demonstrate their potential value, but product, maintenance, and staff training costs may deter hospitals from acquiring these devices. Coating surfaces with copper or silver is another approach that has recently begun to generate interest, and seven studies of coated surfaces have been published.

A major limitation of the evidence base, which KIs highlighted frequently, is the gap between appropriate use of surface cleaning/disinfection agents in studies and practical implementation in real-world settings. While surface disinfectants work best when applied properly to all relevant surfaces for a sufficient contact time, factors such as the consistency of chemical concentration and the effect of hard water on the disinfectants play a role in the products' efficacy. In addition, manufacturers typically provide recommendations for proper use of their products, but most studies do not report thoroughness of cleaning or adherence to disinfectant contact time; this information also remains largely unknown in daily practice. If studies do not ensure adequate application and contact time of chemical agents, results may be biased against a given product or in favor of an alternative, newer modality. Conversely, if study results reflect a product's optimal use, failure to adhere to appropriate product application and contact time in practice may lead to suboptimal outcomes. An important related concern, voiced by KIs and peer reviewers, is uncertainty by end users about the applicability of some manufacturer recommendations. Guidance that accompanies products may be based on laboratory testing under ideal conditions rather than clinical settings. Recommendations may also be developed based on certain types of pathogens, but users may choose to implement a product or technology for broader effects.

Another challenge to interpreting the results of EC studies is the role of many confounding factors, including patient factors, hand hygiene, and other direct patient care practices that affect the risk of HAIs. Infection prevention within the hospital setting comprises many critical components in addition to hard surface cleaning, including sterilization of instruments, laundering of linens, implementation of appropriate isolation precautions, and proper hand washing/hygiene. These and other elements may sometimes be included as interventions within a larger multicomponent infection prevention strategy, limiting the ability to discern the specific impact of any single disinfection approach. These factors also have the potential to modify the effectiveness of EC interventions. Almost every KI emphasized that proper hand hygiene is the most important step for preventing HAIs and that failure to achieve good hand-hygiene practices can minimize the value of surface cleaning and disinfection techniques.

## Monitoring Modalities

Visual inspection was the traditional method employed by EVS personnel and supervisors to ensure that rooms were cleaned adequately. Recently emerging monitoring modalities such as ATP and UV detection of fluorescent markers were examined in 5 studies and 8 studies, respectively. Aerobic colony counts (ACCs) were also used to evaluate surface microbial contamination in 4 studies.

As with cleaning and disinfection modalities, lack of direct comparisons between techniques is a major limitation of the evidence base for monitoring strategies. None of the studies identified by the literature searches for monitoring modalities was an RCT, and fewer than half used any comparative study design. Hospitals are therefore reluctant to adopt ATP and UV, according to several KIs, because these strategies have not been compared head-to-head.

An additional limitation of these studies is the lack of consensus for thresholds of cleanliness. Studies of bioluminescent markers typically report results in RLUs, but benchmarks for RLU levels have not been established. Similarly, thresholds for ACCs are not clearly delineated. This problem is not relevant for studies of UV light, where a threshold of total marker removal is widely accepted. Without commonly agreed-upon measures of key outcomes, selection of optimal approaches is difficult. Inclusion of feedback from various stakeholders, especially EVS management, is also key when deciding appropriate measures to use.

## Additional Considerations

Two important limitations of this review should be noted. One is the restriction of this Technical Brief to studies of C. difficile, MRSA, and VRE. These pathogens have high incidence rates, cause significant patient morbidity, and are frequently targeted in studies of EC. By excluding studies that focused on gram-negative or other organisms to limit the scope of the Brief, our findings may not be fully generalizable to interventions aimed at reducing other types of infections. Future research should seek to review the evidence base for other pathogens. Further, many of the studies included in this review were undertaken during outbreaks and may not be representative of the effect of cleaning/disinfection and monitoring during routine periods of patient care.

Additionally, the limited breadth of evidence does not provide clear guidance on where and when to implement many of these interventions. For example, hospitals may seek to determine whether and how to prioritize the deployment of no-touch technologies (e.g., terminal cleaning after discharge of a patient with C. difficile), but the studies reviewed in this Technical Brief do not provide direct evidence on the effectiveness of competing strategies in different settings. Similarly, the results of a study that examined terminal cleaning after discharge may not be generalizable to routine cleaning of nondischarge rooms, and vice versa. The evidence base provides important insights into the potential effectiveness of numerous EC strategies, but further research is needed to clarify the optimal context for their use.

## Next Steps (Guiding Question 4)

Several important gaps in the current evidence base limit efforts to improve infection prevention programs and reduce HAI rates. Four important questions shape the evidence needs we have identified: (1) What surfaces should be cleaned and disinfected? (2) How should surfaces be cleaned and disinfected? (3) How should cleaning and disinfection be monitored and measured? and (4) How should interventions be implemented?

### 1 What Surfaces Should Be Cleaned and Disinfected?

A limitation of the overall evidence base on EC is uncertainty regarding which surfaces should be targeted during cleaning and disinfection. The scope of this Technical Brief was limited to HTOs. Focusing on surfaces that most frequently come into contact with both patients and health care workers is practical, but consensus is weak on which specific objects have the highest risk of transmitting HAIs. Studies of cleaning, disinfection, and monitoring modalities vary widely when selecting surfaces to evaluate, and some studies focus only on 2 or 3 surfaces while others assess 15 or more, thus making it difficult to determine which surfaces are at greatest risk of microbial contamination and infection transmission. KIs also expressed concern that almost no evidence exists to clarify whether any one specific surface presents greater risk of pathogen transmission to patients than another, and that further work was necessary to establish which objects and surfaces were “high-risk,” rather than merely “high-touch.” Future research should identify which objects and surfaces pose the greatest risk of transmission of pathogens and determine how risk varies by type of pathogen. Studies that correlate surface contamination with patient colonization or infection will be important for clarifying which surfaces require the greatest attention from EVS personnel.

### 2 How Should Surfaces Be Cleaned and Disinfected?

Certain chemical-based cleaning and disinfecting agents, including QAC and bleach, are widely used and have been studied in many settings. However, most studies have employed historical controls and have focused on documenting removal of surface contamination. Head-to-head comparisons that measure patient-centered outcomes, such as colonization or infection rates, are necessary to provide data on their comparative effectiveness. Similarly, numerous studies have examined no-touch devices that employ hydrogen peroxide vapor or emit ultraviolet light, but most studies have not compared them directly to each other, or to various touch modalities. In addition to these approaches, there are several emerging technologies that require further research to establish their efficacy for removing or preventing surface contamination, as well as evaluating their effectiveness for reducing pathogen transmission and patient infection. These include enhanced surface coatings, peracetic acid or hydrogen peroxide wipes, microfiber mops and cloths, and electrolyzed water. Future research should assess these approaches with consideration of the limitations we have described throughout this Technical Brief and EPA regulations for registering products (http://www.epa.gov/pesticides/regulating/laws.htm).

### 3 How Should Cleaning and Disinfection Be Monitored and Measured?

Similarly, more studies are needed that examine how cleanliness is monitored. Future research should evaluate the comparative effectiveness of ATP, ultraviolet light, and ACCs, as compared to each other as well as the standard practice of visual observation. RCTs that provide head-to-head comparisons of patient-centered outcomes may be difficult to implement, but nonrandomized comparative studies examining surrogate outcomes can provide valuable data. Additionally, without validated benchmarks or widespread consensus on what thresholds of surface contamination are safe or acceptable, interpreting and comparing studies on the effectiveness of cleaning, disinfection, and monitoring tools will be difficult. Further research is necessary to correlate the cleanliness metrics that are measured by these modalities with clinical outcomes such as patient colonization or infection. Finally, the use of polymerase chain reaction (PCR)-based assays for assessing surface contamination is an emerging field for future study.

### 4 How Should Interventions Be Implemented?

Factors that affect real-world implementation are crucial but are rarely studied systematically or in depth. While previous studies have addressed organizational culture, staff training, and feedback cycles, there remains little understanding about the effect of these factors on HAIs. Important considerations of implementation, including how programs are sustained and the frequency and impact of EVS outsourcing, also require study.

Table 5 summarizes the additional evidence needed to optimize environmental cleaning of standard inpatient hospital rooms. It is based on the PICOTS structure, but the population and setting are not explicitly noted, because they are the same for each intervention listed: inpatient rooms in general medical and surgical units, as described in the Methods section. For each intervention described in the report, we have identified research needs that are not adequately met in the current literature, and categorized them by the following criteria: Comparator, which indicates which standard or alternative interventions would be appropriate for comparison; Outcomes, which identifies which of three primary outcomes (surface contamination, patient colonization, or patient infection) are needed for evaluating the effectiveness of an intervention; Timing, which indicates whether the intervention should be tested for routine, daily cleaning of hospital rooms, or terminal cleaning; and Study Design, which suggests what types of studies are necessary to assess each comparison and outcome.

Table 5 Evidence needs for environmental cleaning of standard inpatient hospital rooms

Intervention Category | Intervention | Comparator | Outcomes | Timing | Study Design
Cleaning and Disinfection: Touch Modalities | Quaternary ammonia compounds (QAC) | Detergents/Chlorine-based disinfectants | Colonization/ Infection | Routine/ Terminal | RCTs/ Nonrandomized concurrent controls
Cleaning and Disinfection: Touch Modalities | Chlorine-based disinfectants | Detergents/ QAC | Colonization/ Infection | Routine/ Terminal | RCTs/ Nonrandomized concurrent controls
Cleaning and Disinfection: Touch Modalities (continued) | Peracetic acid or HP wipes | Standard care | Contamination | Routine | Historical controls
Cleaning and Disinfection: Touch Modalities (continued) | Peracetic acid or HP wipes | All other touch modalities | Contamination/ Colonization/ Infection | Routine | Any
Cleaning and Disinfection: Touch Modalities (continued) | Microfiber | Standard mops/towels | Contamination | Routine | Historical controls
Cleaning and Disinfection: Touch Modalities (continued) | Microfiber | Other touch modalities | Contamination/ Colonization/ Infection | Routine | Any
Cleaning and Disinfection: Touch Modalities (continued) | Electrolyzed Water | Standard care | Contamination | Routine | Historical controls/ Laboratory testing
Cleaning and Disinfection: No-Touch Modalities | Ultraviolet light emitting | Touch modalities | Colonization/ Infection | Terminal | RCTs/ Nonrandomized concurrent controls
Cleaning and Disinfection: No-Touch Modalities | Ultraviolet light emitting | Hydrogen peroxide vapor | Contamination/ Colonization/ Infection | Terminal | RCTs/ Nonrandomized concurrent controls
Cleaning and Disinfection: No-Touch Modalities | Hydrogen peroxide vapor | Touch modalities | Colonization/ Infection | Terminal | RCTs/ Nonrandomized concurrent controls
Cleaning and Disinfection: No-Touch Modalities | Hydrogen peroxide vapor | Ultraviolet light emitting | Contamination/ Colonization/ Infection | Terminal | RCTs/ Nonrandomized concurrent controls
Cleaning and Disinfection: No-Touch Modalities | Coatings | All touch and non-touch modalities | Contamination/ Colonization/ Infection | Routine/ Terminal | Any
Cleaning and Disinfection: Additional Considerations | Identifying “high-risk” surfaces | Comparisons between high-touch surfaces | Contamination/ Colonization/ Infection | Routine | Nonrandomized concurrent controls/ Laboratory testing
Monitoring | ATP | Visual inspection | Colonization/ Infection | Terminal | Nonrandomized concurrent controls
Monitoring | ATP | Ultraviolet light/ Aerobic colony counts | Contamination/ Colonization/ Infection | Terminal | RCTs/ Nonrandomized concurrent controls
Monitoring | Ultraviolet light | Visual inspection | Colonization/ Infection | Terminal | Nonrandomized concurrent controls
Monitoring | Ultraviolet light | ATP/ Aerobic colony counts | Contamination/ Colonization/ Infection | Terminal | RCTs/ Nonrandomized concurrent controls
Monitoring | Aerobic colony counts | Visual inspection | Colonization/ Infection | Terminal | Nonrandomized concurrent controls
Monitoring | Aerobic colony counts | ATP/ Ultraviolet light | Contamination/ Colonization/ Infection | Terminal | RCTs/ Nonrandomized concurrent controls
Monitoring: Additional Consideration | Setting thresholds for “cleanliness” | Contamination measures | Colonization/ Infection | Routine/ Terminal | Nonrandomized concurrent controls
Implementation: Structural Characteristics | Outsourcing | In-house staff | Adherence to standards/ Contamination/ Colonization/ Infection | Routine/ Terminal | Nonrandomized concurrent controls/ Historical controls
Implementation: Management Tools | Training and educational interventions | N/A | Adherence to standards/ Contamination/ Colonization/ Infection | Routine/ Terminal | Nonrandomized concurrent controls/ Historical controls
Implementation: Management Tools | Feedback cycles | N/A | Adherence to standards/ Contamination/ Colonization/ Infection | Routine/ Terminal | Nonrandomized concurrent controls/ Historical controls

ATP=adenosine triphosphate; N/A=not applicable; QAC=quaternary ammonia compounds; RCT=randomized controlled trial

## Additional Considerations for Future Research

As represented in Table 5 and Figure 6, there are two additional factors that must be considered in designing and prioritizing future research efforts: selection of appropriate patient-centered outcomes, and designing research studies that are practical and useful.

### Patient-Centered Outcomes

The current evidence base does not demonstrate strong correlation between cleaning, disinfection, monitoring, and HAIs. Surface contamination is the most common outcome reported in studies of cleaning/disinfection and monitoring strategies. Patient infection rates are less frequently measured, although they were reported in 15 studies. Patient colonization measures were rarely recorded, but a few KIs suggested that pathogen acquisition is a useful surrogate outcome that should be measured and reported in studies of EC. Among the potential advantages of measuring acquisition is that it is a more clinically meaningful outcome than surface contamination and a more frequent outcome than infection and thus provides studies with more power to detect meaningful differences between interventions. Baseline infection rates within the study populations are also important factors for understanding the evidence. Since many of the studies in this review occurred during outbreaks, the effect size of interventions may have been overestimated.

Patients also have preferences in addition to clinical outcomes. KIs reported that patients often expect their room to “look and smell clean.” Although these preferences are imprecise and may not correlate with scientific measures of cleanliness, patients may express concerns to hospital staff or management or through satisfaction surveys when expectations are not met.

### Research Design

Most studies do not directly compare the effectiveness of different techniques. Instead, most used historical controls, such as before-and-after or interrupted time-series study designs, to assess the impact of a single disinfection modality. Although such studies are valuable for establishing baseline measures of effectiveness, they do not demonstrate which approaches might be optimal. Direct comparative-effectiveness data are necessary to guide optimal selection of cleaning/disinfection agents and technologies. Second, RCTs are not always feasible for studying EC interventions.141 Patient-centered outcomes such as HAI rates often do not occur with enough frequency to be easily detected by modest-sized RCTs. This is further complicated by the complex environment of pathogen transmission and the interaction of disinfection strategies with many other factors such as hand hygiene. Given these challenges, well-designed observational studies may provide crucial evidence to guide EC practices.

It is also important to control for confounders and multicomponent interventions in these studies. Innovative approaches for designing or analyzing studies are necessary to discern the specific impact of EC strategies within the larger context of infection prevention programs and hand-hygiene compliance for preventing HAIs. This Technical Brief did not identify any specific published models or strategies that might guide efforts to control for confounding by other infection prevention strategies.

### Funding Future Research

Studies of EC are most often funded by manufacturers of cleaning agents or disinfection technologies, creating potential conflicts of interest. These conflicts introduce real or perceived biases into the evidence base and may lead to skepticism by EVS professionals and infection control experts about the results of these studies. Our KIs indicated that concerns about industry funding of published research may deter adoption of disinfection and monitoring technologies. While it is reasonable to expect that manufacturers should be the primary source of funding for early studies of newly emerging technologies, it is important for less conflicted funders to assume a major role in comparative-effectiveness research in this domain.