# References

1 Weber DJ, Rutala WA, Miller MB, et al. Role of hospital surfaces in the transmission of emerging health care-associated pathogens: norovirus, Clostridium difficile, and Acinetobacter species. Am J Infect Control. Jun. 2010;38(5 Suppl 1):S25-33. http://dx.doi.org/10.1016/j.ajic.2010.04.196. [pmid: 20569853].
2 Dancer SJ. Importance of the environment in meticillin-resistant Staphylococcus aureus acquisition: the case for hospital cleaning. Lancet Infect Dis. Feb. 2008;8(2):101-13. http://dx.doi.org/10.1016/S1473-3099(07)70241-4. [pmid: 17974481].
3 Drees M, Snydman DR, Schmid CH, et al. Prior environmental contamination increases the risk of acquisition of vancomycin-resistant enterococci. Clin Infect Dis. Mar. 1. 2008;46(5):678-85. http://dx.doi.org/10.1086/527394. [pmid: 18230044].
4 Weber DJ, Anderson D, Rutala WA. The role of the surface environment in healthcare-associated infections. Curr Opin Infect Dis. Aug. 2013;26(4):338-44. [pmid: 23743816].
5 Wagenvoort JH, Sluijsmans W, Penders RJ. Better environmental survival of outbreak vs. sporadic MRSA isolates. J Hosp Infect. Jul. 2000;45(3):231-4. http://dx.doi.org/10.1053/jhin.2000.0757. [pmid: 10896803].
6 Wendt C, Wiesenthal B, Dietz E, et al. Survival of vancomycin-resistant and vancomycin-susceptible enterococci on dry surfaces. J Clin Microbiol. Dec. 1998;36(12):3734-6. [pmid: 9817912].
7 Kramer A, Schwebke I, Kampf G. How long do nosocomial pathogens persist on inanimate surfaces? A systematic review. BMC Infect Dis. 2006. Aug. 16. http://dx.doi.org/10.1186/1471-2334-6-130. [pmid: 16914034].
8 Kim KH, Fekety R, Batts DH, et al. Isolation of Clostridium difficile from the environment and contacts of patients with antibiotic-associated colitis. J Infect Dis. Jan. 1981;143(1):42-50. [pmid: 7217711].
9 Jinadatha C, Quezada R, Huber TW, et al. Evaluation of a pulsed-xenon ultraviolet room disinfection device for impact on contamination levels of methicillin-resistant Staphylococcus aureus. BMC Infect Dis. 2014;14(1):187. [pmid: 24708734].
10 Qureshi Z, Yassin MH. Role of ultraviolet (UV) disinfection in infection control and environmental cleaning. Infect Disord Drug Targets. Jun. 2013;13(3):191-5. [pmid: 23961739].
11 ECRI Institute. Ultraviolet light environmental disinfection systems. Plymouth Meeting (PA). ECRI Institute. 2012. Feb. 16. 7 p. (Hotline Response).
12 Passaretti CL, Otter JA, Reich NG, et al. An evaluation of environmental decontamination with hydrogen peroxide vapor for reducing the risk of patient acquisition of multidrug-resistant organisms. Clin Infect Dis. Jan. 2013;56(1):27-35. [pmid: 23042972].
13 Manian Farrin A, Griesnauer S, Bryant A. Implementation of hospital-wide enhanced terminal cleaning of targeted patient rooms and its impact on endemic Clostridium difficile infection rates. Am J Infect Control. Jun. 1. 2013;41(6):537-42. [pmid: 23219675].
14 ECRI Institute. Hydrogen peroxide vapor technology for decontaminating health facilities. Plymouth Meeting (PA). ECRI Institute. 2012. Nov. 16 p. (Hotline Response).
15 ECRI Institute. Copper surfaces in the intensive care unit for preventing hospital-acquired infections. Plymouth Meeting (PA). ECRI Institute. 2013. Apr. 9 p. (Health Technology Forecast).
16 Salgado CD, Sepkowitz KA, John JF, et al. Copper surfaces reduce the rate of healthcare-acquired infections in the intensive care unit. Infect Control Hosp Epidemiol. May. 2013;34(5):479-86. [pmid: 23571364].
17 Snyder GM, Holyoak AD, Leary KE, et al. Effectiveness of visual inspection compared with non-microbiologic methods to determine the thoroughness of post-discharge cleaning. Antimicrob Resist Infect Control. 2013;2(1):26. [pmid: 24088298].
18 Mulvey D, Redding P, Robertson C, et al. Finding a benchmark for monitoring hospital cleanliness. J Hosp Infect. Jan. 2011;77(1):25-30. [pmid: 21129820].
19 Sherlock O, O'Connell N, Creamer E, et al. Is it really clean? An evaluation of the efficacy of four methods for determining hospital cleanliness. J Hosp Infect. Jun. 2009;72(2):140-6. [pmid: 19321226].
20 Omidbakhsh N, Ahmadpour F, Kenny N. How reliable are ATP bioluminescence meters in assessing decontamination of environmental surfaces in healthcare settings?. PLoS ONE. Jun. 18. 2014;9(6):e99951. [pmid: 24940751].
21 Shama G, Malik DJ. The uses and abuses of rapid bioluminescence-based ATP assays. Int J Hyg Environ Health. Mar. 2013;216(2):115-25. http://dx.doi.org/10.1016/j.ijheh.2012.03.009. [pmid: 22541898].
22 Sciortino CV, Giles RA. Validation and comparison of three adenosine triphosphate luminometers for monitoring hospital surface sanitization: a Rosetta Stone for adenosine triphosphate testing. Am J Infect Control. Oct. 2012;40(8):e233-e239. [pmid: 23021416].
23 Rutala WA, Weber DJ, Healthcare Infection Control Practices Advisory Committee. Guideline for disinfection and sterilization in healthcare facilities, 2008. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2008. 158 p. http://www.cdc.gov/hicpac/Disinfection_Sterilization/17_00Recommendations.html.
24 Best M, Sattar SA, Springthorpe VS, et al. Efficacies of selected disinfectants against Mycobacterium tuberculosis. J Clin Microbiol. Oct. 1990;28(10):2234-9. [pmid: 2121783].
25 Sattar SA, Springthorpe VS, Karim Y, et al. Chemical disinfection of non-porous inanimate surfaces experimentally contaminated with four human pathogenic viruses. Epidemiol Infect. Jun. 1989;102(3):493-505. [pmid: 2737256].
26 Engelbrecht K, Ambrose D, Sifuentes L, et al. Decreased activity of commercially available disinfectants containing quaternary ammonium compounds when exposed to cotton towels. Am J Infect Control. Oct. 2013;41(10):908-11. [pmid: 23623007].
27 Purohit A, Kopferschmitt-Kubler MC, Moreau C, et al. Quaternary ammonium compounds and occupational asthma. Int Arch Occup Environ Health. Aug. 2000;73(6):423-7. [pmid: 11007347].
28 Bernstein JA, Stauder T, Bernstein DI, et al. A combined respiratory and cutaneous hypersensitivity syndrome induced by work exposure to quaternary amines. J Allergy Clin Immunol. Aug. 1994;94(2 Pt 1):257-9. [pmid: 8064078].
29 Rutala WA, Weber DJ. Uses of inorganic hypochlorite (bleach) in health-care facilities. Clin Microbiol Rev. Oct. 1997;10(4):597-610. [pmid: 9336664].
30 Rutala WA, Cole EC, Thomann CA, et al. Stability and bactericidal activity of chlorine solutions. Infect Control Hosp Epidemiol. May. 1998;19(5):323-7. [pmid: 9613692].
31 Landau GD, Saunders WH. The effect of chlorine bleach on the esophagus. Arch Otolaryngol. Aug. 1964;80:174-6. [pmid: 14160140].
32 Mrvos R, Dean BS, Krenzelok EP. Home exposures to chlorine/chloramine gas: review of 216 cases. South Med J. Jun. 1993;86(6):654-7. [pmid: 8506487].
33 Reisz GR, Gammon RS. Toxic pneumonitis from mixing household cleaners. Chest. Jan. 1986;89(1):49-52. [pmid: 3940787].
34 Omidbakhsh N, Sattar SA. Broad-spectrum microbicidal activity, toxicologic assessment, and materials compatibility of a new generation of accelerated hydrogen peroxide-based environmental surface disinfectant. Am J Infect Control. Jun. 2006;34(5):251-7. [pmid: 16765201].
35 Bloomfield SF, Miller EA. A comparison of hypochlorite and phenolic disinfectants for disinfection of clean and soiled surfaces and blood spillages. J Hosp Infect. Apr. 1989;13(3):231-9. [pmid: 2567752].
36 Rudensky B, Eidelman AI, Isacsohn M. Phenol and neonatal jaundice. Pediatrics. Sep. 1980;66(3):476-7. [pmid: 7422441].
37 Wysowski DK, Flynt JW Jr, Goldfield M, et al. Epidemic neonatal hyperbilirubinemia and use of a phenolic disinfectant detergent. Pediatrics. Feb. 1978;61(2):165-70. [pmid: 634666].
38 Schmidt MG, Attaway HH, Sharpe PA, et al. Sustained reduction of microbial burden on common hospital surfaces through introduction of copper. J Clin Microbiol. Jul. 2012;50(7):2217-23. [pmid: 22553242].
39 Weber DJ, Rutala WA. Self-disinfecting surfaces: Review of current methodologies and future prospects. Am J Infect Control. May. 2013;41(5 Suppl):S31-5. [pmid: 23622745].
40 Brady MJ, Lisay CM, Yurkovetskiy AV, et al. Persistent silver disinfectant for the environmental control of pathogenic bacteria. Am J Infect Control. Jun. 2003;31(4):208-14. [pmid: 12806357].
41 Chung KK, Schumacher JF, Sampson EM, et al. Impact of engineered surface microtopography on biofilm formation of Staphylococcus aureus. Biointerphases. Jun. 2007;2(2):89-94. [pmid: 20408641].
42 Decraene V, Pratten J, Wilson M. An assessment of the activity of a novel light-activated antimicrobial coating in a clinical environment. Infect Control Hosp Epidemiol. Dec. 2008;29(12):1181-4. http://dx.doi.org/10.1086/592413. [pmid: 18950278].
43 Ismail S, Perni S, Pratten J, et al. Efficacy of a novel light-activated antimicrobial coating for disinfecting hospital surfaces. Infect Control Hosp Epidemiol. Nov. 2011;32(11):1130-2. [pmid: 22011544].
44 Wilson M. Light-activated antimicrobial coating for the continuous disinfection of surfaces. Infect Control Hosp Epidemiol. Oct. 2003;24(10):782-4. http://dx.doi.org/10.1086/502136. [pmid: 14587947].
45 Rutala WA, Gergen MF, Tande BM, et al. Rapid hospital room decontamination using ultraviolet (UV) light with a nanostructured UV-refiective wall coating. Infect Control Hosp Epidemiol. May. 2013;34(5):527-9. [pmid: 23571373].
46 Cooper RA, Griffith CJ, Malik RE, et al. Monitoring the effectiveness of cleaning in four British hospitals. Am J Infect Control. Jun. 2007;35(5):338-41. [pmid: 17577482].
47 Griffith CJ, Cooper RA, Gilmore J, et al. An evaluation of hospital cleaning regimes and standards. J Hosp Infect. May. 2000;45(1):19-28. [pmid: 10833340].
48 Sherlock O, O'Connell N, Creamer E, et al. Is it really clean? An evaluation of the efficacy of four methods for determining hospital cleanliness. J Hosp Infect. Jun. 2009;72(2):140-6. [pmid: 19321226].
49 Lemmen SW, Hafner H, Zolldann D, et al. Comparison of two sampling methods for the detection of gram-positive and gram-negative bacteria in the environment: moistened swabs versus Rodac plates. Int J Hyg Environ Health. Mar. 2001;203(3):245-8. http://dx.doi.org/10.1078/S1438-4639(04)70035-8. [pmid: 11279821].
50 Boyce JM, Havill NL, Havill HL, et al. Comparison of fluorescent marker systems with 2 quantitative methods of assessing terminal cleaning practices. Infect Control Hosp Epidemiol. Dec. 2011;32(12):1187-93. [pmid: 22080657].
51 Branch-Elliman W, Robillard E, McCarthy G, et al. Direct feedback with the ATP luminometer as a process improvement tool for terminal cleaning of patient rooms. Am J Infect Control. Feb. 2014;42(2):195-7. [pmid: 24485376].
52 Koll BS, Ruiz RE, Calfee DP, et al. Prevention of hospital-onset Clostridium difficile infection in the New York metropolitan region using a collaborative intervention model. Journal for healthcare quality: official publication of the National Association for Healthcare Quality. May-Jun. 2014;36(3):35-45. [pmid: 23294050].
53 Ramphal L, Suzuki S, McCracken IM, et al. Improving hospital staff compliance with environmental cleaning behavior. Proc (Bayl Univ Med Cent). Apr. 2014;27(2):88-91. [pmid: 24688183].
54 Rupp ME, Fitzgerald T, Sholtz L, et al. Maintain the gain: Program to sustain erformance improvement in environmental cleaning. Infect Control Hosp Epidemiol. Jul. 2014;35(7):866-8. [pmid: 24915215].
55 Rupp ME, Huerta T, Cavalieri RJ, et al. Optimum outlier model for potential improvement of environmental cleaning and disinfection. Infection control and hospital epidemiology: the official journal of the Society of Hospital Epidemiologists of America. Jun. 2014;35(6):721-3. [pmid: 24799650].
56 Smith PW, Beam E, Sayles H, et al. Impact of adenosine triphosphate detection and feedback on hospital room cleaning. Infect Control Hosp Epidemiol. May. 2014;35(5):564-9. [pmid: 24709726].
57 Brakovich B, Bonham E, VanBrackle L. War on the spore: Clostridium difficile disease among patients in a long-term acute care hospital. Journal for healthcare quality: official publication of the National Association for Healthcare Quality. May-Jun. 2013;35(3):15-21. [pmid: 22304334].
58 Murphy CL, MacBeth DA, Derrington P, et al. An assessment of high touch object cleaning thoroughness using a fluorescent marker in two Australian hospitals. Healthc Infect. 2011;16(4):156-63.
59 Trajtman AN, Manickam K, Macrae M, et al. Continuing performance feedback and use of the ultraviolet visible marker to assess cleaning compliance in the healthcare environment. J Hosp Infect. Jun. 2013;84(2):166-72. [pmid: 23631799].
60 Ragan K, Khan A, Zeynalova N, et al. Use of audit and feedback with fluorescent targeting to achieve rapid improvements in room cleaning in the intensive care unit and ward settings. Am J Infect Control. Apr. 2012;40(3):284-6. [pmid: 21820762].
61 Datta R, Platt R, Yokoe DS, et al. Environmental cleaning intervention and risk of acquiring multidrug-resistant organisms from prior room occupants. Arch Intern Med. Mar. 28. 2011;171(6):491-4. [pmid: 21444840].
62 Hota B, Blom DW, Lyle EA, et al. Interventional evaluation of environmental contamination by vancomycin-resistant enterococci: failure of personnel, product, or procedure?. J Hosp Infect. Feb. 2009;71(2):123-31. [pmid: 19108932].
63 Po JL, Burke R, Sulis C, et al. Dangerous cows: an analysis of disinfection cleaning of computer keyboards on wheels. Am J Infect Control. Nov. 2009;37(9):778-80. [pmid: 19457585].
64 Carling PC, Parry MM, Rupp ME, et al. Improving cleaning of the environment surrounding patients in 36 acute care hospitals. Infect Control Hosp Epidemiol. Nov. 2008;29(11):1035-41. [pmid: 18851687].
65 Goodman ER, Platt R, Bass R, et al. Impact of an environmental cleaning intervention on the presence of methicillin-resistant Staphylococcus aureus and vancomycin-resistant enterococci on surfaces in intensive care unit rooms. Infect Control Hosp Epidemiol. Jul. 2008;29(7):593-9. [pmid: 18624666].
66 Eckstein BC, Adams DA, Eckstein EC, et al. Reduction of Clostridium Difficile and vancomycin-resistant Enterococcus contamination of environmental surfaces after an intervention to improve cleaning methods. BMC Infect Dis. Jun. 21. 2007;7:61. [pmid: 17584935].
67 Hayden MK, Bonten MJ, Blom DW, et al. Reduction in acquisition of vancomycin-resistant enterococcus after enforcement of routine environmental cleaning measures. Clin Infect Dis. Jun. 1. 2006;42(11):1552-60. [pmid: 16652312].
68 Shekelle PG, Wachter RM, Pronovost PJ, et al. Making health care safer II: an updated critical analysis of the evidence for patient safety practices. (Prepared by the Southern California-RAND Evidence-based Practice Center under contract no. 290-2007-10062-I). Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2013. Mar. 945 p. (Comparative effectiveness review; no.211). http://www.ahrq.gov/research/findings/evidence-based-reports/ptsafetyuptp.html.
69 Shekelle PG, Pronovost PJ, Wachter RM, et al. Assessing the evidence for contextsensitive effectiveness and safety of patient safety practices: developing criteria. Contract final report. AHRQ publication no. 11-0006-EF. (Prepared by RAND Health under contract HHSA-290-2009-10001C with the Agency for Healthcare Research and Quality). Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2010. Dec. 81 p. http://archive.ahrq.gov/research/findings/final-reports/contextsensitive/context.pdf.
70 Health care. Gaithersburg (MD). Sodexo. http://www.sodexo.com/en/services/on-site/health-care/offer.aspx. 2014 Oct 09.
71 Feczko R, Polizzi T, Schweon SJ, et al. Crothall Healthcare's strategic initiatives for reducing healthcare-associated infections. Wayne (PA). Crothall Healthcare. 2012. May. http://media.crothall.com/global/Crothall%20IP%20White%20Paper%20-%20May%202012%20%28FINAL%29.pdf. 2014 Oct 09.
72 Sterilants and disinfectants in healthcare facilities. Healthcare Environmental Resource Center. http://www.hercenter.org/hazmat/steril.cfm. 2014 Oct 03.
73 Fact sheets: CMS proposals to improve quality of care during hospital inpatient stays. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). 2014. Apr. 30. http://www.cms.gov/Newsroom/MediaReleaseDatabase/Fact-sheets/2014-Fact-sheets-items/2014-04-30-2.html. 2014 Oct 21.
74 Raveis VH, Conway LJ, Uchida M, et al. Translating infection control guidelines into practice: implementation process within a health care institution. Qual Health Res. Apr. 2014;24(4):551-60. [pmid: 24598775].
75 Clarke SP. Organizational climate and culture factors. Annu Rev Nurs Res. 2006;24:255-72. [pmid: 17078417].
76 Guh A, Carling P, Environmental Evaluation Workgroup, Division of Healthcare Quality Promotion, National Center for Emerging, Zoonotic and Infectious Diseases. Options for evaluating environmental cleaning. [Toolkit]. 2010. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2010. Dec. 15 p. http://www.cdc.gov/HAI/pdfs/toolkits/Environ-Cleaning-Eval-Toolkit12-2-2010.pdf.
77 Sehulster L, Chinn RY, CDC, et al. Guidelines for environmental infection control in health-care facilities. Recommendations of CDC and the Healthcare Infection Control Practices Advisory Committee (HICPAC). [Published errata appear in MMWR Recomm Rep 2003 Oct 24;52(42):1025-6]. MMWR Recomm Rep. Jun. 6. 2003;52(RR-10):1-42. [pmid: 12836624].
78 Association for Professionals in Infection Control and Epidemiology, Inc. Guide to preventing clostridium difficile infections. Washington (DC). Association for Professionals in Infection Control and Epidemiology, Inc. 2013. Feb. 100 p. http://www.apic.org/Resource_/EliminationGuideForm/59397fc6-3f90-43d1-9325-e8be75d86888/File/2013CDiffFinal.pdf.
79 Mitchell BG, Digney W, Locket P, et al. Controlling methicillin-resistant Staphylococcus aureus (MRSA) in a hospital and the role of hydrogen peroxide decontamination: an interrupted time series analysis. BMJ Open. 2014;4(4):e004522. [pmid: 24747791].
80 Goldenberg SD, Patel A, Tucker D, et al. Lack of enhanced effect of a chlorine dioxide-based cleaning regimen on environmental contamination with Clostridium difficile spores. J Hosp Infect. Sep. 2012;82(1):64-7. [pmid: 22795136].
81 Carter Y, Barry D. Tackling C difficile with environmental cleaning. Nurs Times. Sep. 13. 2011;107(36):22-6. [pmid: 21998939].
82 Whitaker J, Brown BS, Vidal S, et al. Designing a protocol that eliminates Clostridium difficile: a collaborative venture. Am J Infect Control. Jun. 2007;35(5):310-4. [pmid: 17577477].
83 Novice to expert: the Dreyfus model of skill acquisition. Stan Lester Developments. http://www.sld.demon.co.uk/dreyfus.pdf. 2014 Oct 13.
84 Friedman ND, Walton AL, Boyd S, et al. The effectiveness of a single-stage versus traditional three-staged protocol of hospital disinfection at eradicating vancomycin-resistant Enterococci from frequently touched surfaces. Am J Infect Control. Mar. 2013;41(3):227-31. [pmid: 22981721].
85 Munoz-Price LS, Ariza-Heredia E, Adams S, et al. Use of UV powder for surveillance to improve environmental cleaning. Infect Control Hosp Epidemiol. Mar. 2011;32(3):283-5. [pmid: 21460514].
86 Gillespie E, Wilson J, Lovegrove A, et al. Environment cleaning without chemicals in clinical settings. Am J Infect Control. May. 2013;41(5):461-3. [pmid: 23177456].
87 Sitzlar B, Deshpande A, Fertelli D, et al. An environmental disinfection odyssey: Evaluation of sequential interventions to improve disinfection of Clostridium difficile isolation rooms. Infect Control Hosp Epidemiol. May. 2013;34(5):459-65. [pmid: 23571361].
88 Fornwalt L, Riddell B. Implementation of innovative pulsed xenon ultraviolet (PX-UV) environmental cleaning in an acute care hospital. Risk Manag Healthc Policy. Jan. 22. 2014;7:25-8. [pmid: 24482577].
89 Alberta Health Services, Provincial Neuro-Oncology Team. Cancer guidelines: CNS germ cell tumours. Edmonton (Alberta). Alberta Health Services. In development.
90 Hacek DM, Ogle AM, Fisher A, et al. Significant impact of terminal room cleaning with bleach on reducing nosocomial Clostridium difficile. Am J Infect Control. Jun. 2010;38(5):350-3. [pmid: 20123150].
91 McMullen KM, Zack J, Coopersmith CM, et al. Use of hypochlorite solution to decrease rates of Clostridium difficile-associated diarrhea. Infect Control Hosp Epidemiol. Feb. 2007;28(2):205-7. [pmid: 17265404].
92 De Lorenzi S, Finzi G, Parmiggiani R, et al. Comparison of floor sanitation methods. J Hosp Infect. Mar. 2006;62(3):346-8. [pmid: 16376456].
93 Schmidt MG, Anderson T, Attaway HH, et al. Patient environment microbial burden reduction: a pilot study comparison of 2 terminal cleaning methods. Am J Infect Control. Aug. 2012;40(6):559-61. [pmid: 21981792].
94 Sjoberg M, Eriksson M, Andersson J, et al. Transmission of Clostridium difficile spores in isolation room environments and through hospital beds. APMIS. Sep. 2014;122(9):800-3. [pmid: 24475890].
95 Hess AS, Shardell M, Kristie Johnson J, et al. A randomized controlled trial of enhanced cleaning to reduce contamination of healthcare worker gowns and gloves with multidrug-resistant bacteria. Infect Control Hosp Epidemiol. May. 2013;34(5):487-93. [pmid: 23571365].
96 Boyce JM, Havill NL. Evaluation of a new hydrogen peroxide wipe disinfectant. Infect Control Hosp Epidemiol. May. 2013;34(5):521-3. [pmid: 23571371].
97 Orenstein R, Aronhalt KC, McManus JE Jr, et al. A targeted strategy to wipe out Clostridium difficile. Infect Control Hosp Epidemiol. Nov. 2011;32(11):1137-9. [pmid: 22011546].
98 Wiemken TL, Curran DR, Pacholski EB, et al. The value of ready-to-use disinfectant wipes: compliance, employee time, and costs. Am J Infect Control. Mar. 2014;42(3):329-30. [pmid: 24581022].
99 Levin J, Riley LS, Parrish C, et al. The effect of portable pulsed xenon ultraviolet light after terminal cleaning on hospital-associated Clostridium difficile infection in a community hospital. Am J Infect Control. Aug. 2013;41(8):746-8. [pmid: 23685092].
100 Haas JP, Menz J, Dusza S, et al. Implementation and impact of ultraviolet environmental disinfection in an acute care setting. Am J Infect Control. Jun. 2014;42(6):586-90. [pmid: 24837107].
101 Manian FA, Griesnauer S, Bryant A. Implementation of hospital-wide enhanced terminal cleaning of targeted patient rooms and its impact on endemic Clostridium difficile infection rates. Am J Infect Control. Jun. 2013;41(6):537-41. [pmid: 23219675].
102 Salgado CD, Sepkowitz KA, John JF, et al. Copper surfaces reduce the rate of healthcare-acquired infections in the intensive care unit. Infect Control Hosp Epidemiol. May. 2013;34(5 Suppl):479-86. [pmid: 23571364].
103 Schmidt MG, Attaway HH, Fairey SE, et al. Copper continuously limits the concentration of bacteria resident on bed rails within the intensive care unit. Infect Control Hosp Epidemiol. May. 2013;34(5 Suppl):530-3. [pmid: 23571374].
104 Hamilton D, Foster A, Ballantyne L, et al. Performance of ultramicrofibre cleaning technology with or without addition of a novel copper-based biocide. J Hosp Infect. Jan. 2010;74(1):62-71. [pmid: 19819583].
105 Casey AL, Adams D, Karpanen TJ, et al. Role of copper in reducing hospital environment contamination. J Hosp Infect. Jan. 2010;74(1):72-7. [pmid: 19931938].
106 Hedin G, Rynback J, Lore B. Reduction of bacterial surface contamination in the hospital environment by application of a new product with persistent effect. J Hosp Infect. Jun. 2010;75(2):112-5. [pmid: 20381907].
107 Karpanen TJ, Casey AL, Lambert PA, et al. The antimicrobial efficacy of copper alloy furnishing in the clinical environment: a crossover study. Infect Control Hosp Epidemiol. Jan. 2012;33(1):3-9. [pmid: 22173515].
108 Falagas ME, Thomaidis PC, Kotsantis IK, et al. Airborne hydrogen peroxide for disinfection of the hospital environment and infection control: a systematic review. J Hosp Infect. Jul. 2011;78(3):171-7. [pmid: 21392848].
109 Dettenkofer M, Wenzler S, Amthor S, et al. Does disinfection of environmental surfaces influence nosocomial infection rates? A systematic review. Am J Infect Control. Apr. 2004;32(2):84-9. [pmid: 15057199].
110 Byers KE, Durbin LJ, Simonton BM, et al. Disinfection of hospital rooms contaminated with vancomycin-resistant Enterococcus faecium. Infect Control Hosp Epidemiol. Apr. 1998;19(4):261-4. [pmid: 9605276].
111 Best EL, Parnell P, Thirkell G, et al. Effectiveness of deep cleaning followed by hydrogen peroxide decontamination during high Clostridium difficile infection incidence. J Hosp Infect. Mar. 12. 2014;87(1):25-33. [pmid: 24746230].
112 Anderson DJ, Gergen MF, Smathers E, et al. Decontamination of targeted pathogens from patient rooms using an automated ultraviolet-C-emitting device. Infect Control Hosp Epidemiol. May. 2013;34(5):466-71. [pmid: 23571362].
113 Sigler V, Hensley S. Persistence of mixed staphylococci assemblages following disinfection of hospital room surfaces. J Hosp Infect. Mar. 2013;83(3):253-6. [pmid: 23374288].
114 Passaretti CL, Otter JA, Reich NG, et al. An evaluation of environmental decontamination with hydrogen peroxide vapor for reducing the risk of patient acquisition of multidrug-resistant organisms. Clin Infect Dis. 2013;56(1):27-35. [pmid: 23042972].
115 Kundrapu S, Sunkesula V, Jury LA, et al. Daily disinfection of high-touch surfaces in isolation rooms to reduce contamination of healthcare workers' hands. Infect Control Hosp Epidemiol. Oct. 2012;33(10):1039-42. [pmid: 22961024].
116 Sexton JD, Tanner BD, Maxwell SL, et al. Reduction in the microbial load on high-touch surfaces in hospital rooms by treatment with a portable saturated steam vapor disinfection system. Am J Infect Control. Oct. 2011;39(8):655-62. [pmid: 21641089].
117 Chan HT, White P, Sheorey H, et al. Evaluation of the biological efficacy of hydrogen peroxide vapour decontamination in wards of an Australian hospital. J Hosp Infect. Oct. 2011;79(2):125-8. [pmid: 21824681].
118 Boyce JM, Havill NL, Moore BA. Terminal decontamination of patient rooms using an automated mobile UV light unit. Infect Control Hosp Epidemiol. Aug. 2011;32(8):737-42. [pmid: 21768755].
119 Wilson AP, Smyth D, Moore G, et al. The impact of enhanced cleaning within the intensive care unit on contamination of the near-patient environment with hospital pathogens: a randomized crossover study in critical care units in two hospitals. Crit Care Med. Apr. 2011;39(4):651-8. [pmid: 21242793].
120 Alfa MJ, Lo E, Wald A, et al. Improved eradication of Clostridium difficile spores from toilets of hospitalized patients using an accelerated hydrogen peroxide as the cleaning agent. BMC Infect Dis. Sep. 15. 2010;10:268. [pmid: 20843348].
121 Andersen BM, Rasch M, Kvist J, et al. Floor cleaning: effect on bacteria and organic materials in hospital rooms. J Hosp Infect. Jan. 2009;71(1):57-65. [pmid: 19013671].
122 Mahida N, Vaughan N, Boswell T. First UK evaluation of an automated ultraviolet-C room decontamination device (Tru-D). J Hosp Infect. Aug. 2013;84(4):332-5. [pmid: 23846236].
123 Grabsch EA, Mahony AA, Cameron DR, et al. Significant reduction in vancomycin-resistant enterococcus colonization and bacteraemia after introduction of a bleach-based cleaning-disinfection programme. J Hosp Infect. Dec. 2012;82(4):234-42. [pmid: 23103245].
124 Havill NL, Moore BA, Boyce JM. Comparison of the microbiological efficacy of hydrogen peroxide vapor and ultraviolet light processes for room decontamination. Infect Control Hosp Epidemiol. May. 2012;33(5):507-12. [pmid: 22476278].
125 Rutala WA, Gergen MF, Weber DJ. Room decontamination with UV radiation. Infect Control Hosp Epidemiol. Oct. 2010;31(10):1025-9. [pmid: 20804377].
126 Wilcox MH, Fawley WN, Wigglesworth N, et al. Comparison of the effect of detergent versus hypochlorite cleaning on environmental contamination and incidence of Clostridium difficile infection. J Hosp Infect. Jun. 2003;54(2):109-14. [pmid: 12818583].
127 Boyce JM, Havill NL, Guercia KA, et al. Evaluation of two organosilane products for sustained antimicrobial activity on high-touch surfaces in patient rooms. Am J Infect Control. Mar. 2014;42(3):326-8. [pmid: 24406256].
128 Nerandzic MM, Cadnum JL, Pultz MJ, et al. Evaluation of an automated ultraviolet radiation device for decontamination of Clostridium difficile and other healthcare-associated pathogens in hospital rooms. BMC Infect Dis. 2010;10:197. [pmid: 20615229].
129 Stewart M, Bogusz A, Hunter J, et al. Evaluating use of neutral electrolyzed water for cleaning near-patient surfaces. Infect Control Hosp Epidemiol. 2014;35(12):1505-10. [pmid: 25419773].
130 Amodio E, Dino C. Use of ATP bioluminescence for assessing the cleanliness of hospital surfaces: a review of the published literature (1990-2012). J Infect Public Health. Mar-Apr. 2014;7(2):92-8. [pmid: 24231159].
131 Mitchell BG, Wilson F, Dancer SJ, et al. Methods to evaluate environmental cleanliness in healthcare facilities. Healthc Infect. 2013;18(1):23-30.
132 Carling PC, Parry MF, Bruno-Murtha LA, et al. Improving environmental hygiene in 27 intensive care units to decrease multidrug-resistant bacterial transmission. Crit Care Med. Apr. 2010;38(4):1054-9. [pmid: 20081531].
133 Blue J, O'Neill C, Speziale P, et al. Use of a fluorescent chemical as a quality indicator for a hospital cleaning program. Can J Infect Control. 2008;23(4):216-9. [pmid: 19350998].
134 Carling PC, Briggs J, Hylander D, et al. An evaluation of patient area cleaning in 3 hospitals using a novel targeting methodology. Am J Infect Control. Oct. 2006;34(8):513-9. [pmid: 17015157].
135 Alfa MJ, Dueck C, Olson N, et al. UV-visible marker confirms that environmental persistence of Clostridium difficile spores in toilets of patients with C. difficile-associated diarrhea is associated with lack of compliance with cleaning protocol. BMC Infect Dis. 2008;8:64. [pmid: 18474086].
136 Carling PC, Parry MF, Von Beheren SM. Identifying opportunities to enhance environmental cleaning in 23 acute care hospitals. Infect Control Hosp Epidemiol. Jan. 2008;29(1):1-7. [pmid: 18171180].
137 Luick L, Thompson PA, Loock MH, et al. Diagnostic assessment of different environmental cleaning monitoring methods. Am J Infect Control. Aug. 2013;41(8):751-2. [pmid: 23380380].
138 Smith PW, Gibbs S, Sayles H, et al. Observations on hospital room contamination testing. Healthc Infect. 2013;18(1):10-3.
139 Al Hamad A, Maxwell S. How clean is clean? Proposed methods for hospital cleaning assessment. J Hosp Infect. Dec. 2008;70(4):328-34. [pmid: 18848370].
140 Malik RE, Cooper RA, Griffith CJ. Use of audit tools to evaluate the efficacy of cleaning systems in hospitals. Am J Infect Control. May. 2003;31(3):181-7. [pmid: 12734526].
141 McDonald LC, Arduino M. Editorial commentary: climbing the evidentiary hierarchy for environmental infection control. Clin Infect Dis. Jan. 2013;56(1):36-9. http://dx.doi.org/10.1093/cid/cis845. [pmid: 23042965].