# Methods

We conducted systematic searches of published and gray literature sources and completed interviews with Key Informants (KIs) representing multiple stakeholder groups.

## Data Collection

### Discussions With Key Informants

We selected KIs with expertise in each of the following areas: infectious disease and infection control, environmental disinfection, hospital epidemiology, microbiology, and managing and implementing EVSs in health care settings. Twelve KIs were interviewed, individually or in pairs.

We asked KIs with expertise in infection control about the advantages and disadvantages of cleaning and disinfecting agents and monitoring strategies, the outcomes most important to infection preventionists and patients, challenges to conducting research on EC, and knowledge gaps that future research should address. We asked KIs with experience in EC processes to discuss operational factors that facilitate or impede cleaning procedures, factors that influence decisionmaking around the selection of cleaning agents and monitoring approaches, training and evaluation of front-line personnel, and other elements that are critical to implementation and sustainability. One KI representing the Centers for Medicare & Medicaid Services (CMS) was asked about federal regulations and hospital oversight, coverage decisions and payment policy, and measures of hospital quality and effectiveness. We sought feedback from the topic nominator about the study protocol (http://effectivehealthcare.ahrq.gov/protocol (http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=1951)), research design, guiding questions, inclusion and exclusion criteria, and overall project goals.

We used KI input to refine the systematic literature search, identify gray literature sources, provide information about ongoing research, confirm evidence limitations, and recommend approaches to help fill these gaps. We also sought KI input to inform our findings for Guiding Questions 2 and 4.

### Gray Literature Search

Gray literature includes reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations that typically do not appear in the peer-reviewed journal literature. For this report, we searched gray literature sources to identify clinical practice guidelines, white papers or position statements, descriptions and evaluations of emerging disinfection technologies and monitoring strategies, and influential perspectives on real-world facilitators and barriers to implementation.

Websites and databases associated with the following institutions were searched using text words: AHRQ, Centers for Disease Control and Prevention (CDC), U.S. Environmental Protection Agency (EPA), OSHA, ECRI Institute Healthcare Standards, Medscape, and the National Guideline Clearinghouse™. To locate ongoing clinical trials of EC to prevent HAIs, we searched ClinicalTrials.gov.

We also searched the websites of relevant professional organizations, including the American Organization for Nurse Executives, Association for the Healthcare Environment, Healthcare Infection Society, Institute for Healthcare Improvement, Society for Healthcare Epidemiology of America, Society of Hospital Medicine, University HealthSystem Consortium, and the American Nurses Credentialing Center's Magnet Recognition Program. We searched conference abstracts published since 2013 by the Association for Professionals in Infection Control and Epidemiology (APIC) and the Infectious Diseases Society of America.

### Published Literature Search

Medical librarians in the EPC Information Center performed systematic literature searches, following established systematic review protocols. We searched the following databases using controlled vocabulary and text words: EMBASE (including EMBASE and MEDLINE records), Cumulative Index to Nursing and Allied Health (CINAHL), the Cochrane Library, and PubMed (unprocessed records only). Searches covered the literature published from January 1, 1990, through February 4, 2015. This time frame was selected because we intended to include contemporary disinfection technologies and monitoring approaches while excluding strategies no longer in use. Additionally, significant advances in hand hygiene and other infection control protocols have emerged during approximately the past 25 years. Older studies may not reflect these important improvements in the clinical environment. Appendix A presents a sample search strategy.

We performed literature screening in duplicate using the database Distiller SR (Evidence Partners, Ottawa, Canada) and screened results for relevancy, with relevant abstracts screened in duplicate. Studies that appeared to fit the scope of the brief were retrieved in full and screened again in duplicate. An independent reviewer randomly verified abstracted data.

We included studies if they addressed a guiding question; examined any inpatient wards (such as general medicine, surgery, critical care, oncology); addressed “high-touch” surfaces; evaluated colonization, infection, or environmental contamination with C. difficile, MRSA, or VRE or included multiple unspecified pathogens that were likely to include the above; and were English-language studies. Studies were excluded if they occurred exclusively in pediatric, ambulatory, operating room, or long-term care settings; addressed only transmission routes that are not inherent to the environmental reservoir (e.g., caregiver hands or stethoscopes, patient and guest personal items, linens) or were in vitro studies that did not collect samples from actual patient rooms. We recognize that by restricting our review's scope to three pathogens and hard surfaces we have omitted other important organisms (e.g., gram-negative pathogens) and vectors of transmission (e.g., curtains). However, based on limitations inherent to writing a technical brief, especially the need to focus the scope as narrowly as possible, we consulted with the KIs to develop inclusion and exclusion criteria (see Table 1).

Table 1 Inclusion and exclusion criteria

Topic | Inclusion | Exclusion
Setting | Patient rooms and isolation rooms in acute care hospital wards in the United States, Canada, Western Europe, and Australia | - Ambulatory care settings; - Long-term care facilities or physical rehabilitation centers; - Surgical suites; - Pediatric hospital wards
Language | English | Non-English
Literature | Systematic reviews, clinical practice guidelines, randomized controlled trials, nonrandomized studies with concurrent or historical controls, observational studies, descriptive studies | In vitro or laboratory studies without specimen selection or testing in patient rooms
Surfaces | High-touch objects with hard, nonporous surfaces | - Soft surface, porous objects; - Linens or curtains; - Invasive medical devices
Pathogens | Infection or contamination with C. difficile, MRSA, VRE; or unspecified pathogens where C. difficile, MRSA and VRE were not explicitly excluded in study | Studies not evaluating C. difficile, MRSA, or VRE
Technology | Products or processes currently available in the United States or undergoing investigational studies | Products or processes not available in the United States or not undergoing investigation
Multicomponent strategies | Multicomponent interventions if change in cleaning, disinfection, or monitoring was a primary or prominent component | Multicomponent interventions if cleaning, disinfection, and monitoring were unchanged or secondary to other components

## Data Organization and Presentation

Descriptive characteristics and outcomes from published studies and gray literature were abstracted and detailed in tables. Relevant data included study design; patient population; hospital characteristics; hand-hygiene policies and similar concurrent infection control procedures; pathogen type; high-touch surfaces cleaned; type of cleaning, disinfection, or monitoring modality; focus and scope of outcome measure and implementation strategy; and analytic technique used to evaluate outcomes. Clinical practice guidelines and systematic reviews were detailed in tables separately from primary studies.

A project team member documented KI interviews during each call. Investigators reviewed and discussed notes to evaluate how KI input confirmed or varied from published evidence. KI discussions also provided insight on emerging disinfection and monitoring strategies, evidence gaps, and human and system factors that affect implementation. These insights were incorporated into the findings.

Findings were organized into an evidence map that chronicles the scope and depth of existing research on cleaning, disinfecting, and monitoring processes, while highlighting important gaps in the evidence base. Published studies, gray literature, and KI perspectives and insights informed the evidence map.