# Peer Reviewers

Before publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Dorothy Borton, R.N., B.S.N., CIC
  Infection Preventionist
  Einstein Medical Center
  Philadelphia, PA
- Mary K. Hayden, M.D.
  Professor of Medicine (Infectious Diseases) and Pathology
  Rush University Medical Center
  Chicago, IL
- L. Clifford McDonald, M.D., FACP, FSHEA
  Senior Advisor for Science and Integrity
  Division of Healthcare Quality Promotion
  Centers for Disease Control and Prevention
  Atlanta, GA
- Gina Pugliese, R.N., M.S., FSHEA
  Vice President
  Premier Safety Institute®
  Chicago IL
- Gary A. Roselle, M.D., FACP
  Director, National Infectious Diseases Service, VA Central Office
  Washington, DC
- Robert A. Weinstein, M.D.
  Professor of Medicine
  Chairman, Division of Infectious Diseases, Stroger Hospital of Cook County
  Chief Operating Officer, Ruth M. Rothstein CORE Center
  Co-Director, Rush Translational Sciences Consortium
  Chicago, IL