# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end users of research. Key Informant input can inform key issues related to the topic of the Technical Brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end users, individuals with potential conflicts may be retained. The Task Order Officer (TOO) and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Michelle Alfa, Ph.D., FCCM
  Principal Investigator
  St. Boniface Research Center
  Winnipeg, Canada
- Philip C. Carling, M.D.
  Professor of Clinical Medicine, Infectious Diseases
  Boston University School of Medicine
  Boston, MA
- Patti Costello
  Executive Director
  Association for the Healthcare Environment
  Chicago, IL
- Mia Gonzales Dean, M.B.A., M.S., P.T., FACHE
  Assistant Executive Director, Support Services
  Hospital of the University of Pennsylvania
  Philadelphia, PA
- Curtis J. Donskey, M.D.
  Associate Professor of Medicine, Case Western Reserve University
  Staff Physician, Infectious Diseases Section
  Louis Stokes Cleveland VA Medical Center
  Cleveland, OH
- Rich Feczko
  National Director
  Compass Crothall Healthcare
  Pittsburgh, PA
- Marilyn Hanchett, R.N.
  Senior Director, Research and Clinical Innovation
  Association for Professionals in Infection Control and Epidemiology
  Washington, DC
- Elaine Larson, RN, PhD, FAAN, CIC
  Anna C. Maxwell Professor of Nursing Research
  Associate Dean for Nursing Research, School of Nursing
  Professor of Epidemiology, Mailman School of Public Health
  Editor, American Journal of Infection Control
  Columbia University
  New York, NY
- Luis Ostrosky-Zeichner, M.D.
  Professor of Medicine and Epidemiology
  The University of Texas Health Science Center at Houston
  Houston, TX
- William Rutala, Ph.D., M.S., M.P.H.
  Professor of Medicine, School of Medicine
  Director, Statewide Program for Infection Control and Epidemiology
  Director, Hospital Epidemiology, Occupational Health and Safety Program
  University of North Carolina
  Chapel Hill, NC
- Daniel Schwartz, M.D., M.B.A.
  Chief Medical Officer
  Survey and Certification Group
  Centers for Medicare and Medicaid Services
  Baltimore, MD
- James P. Steinberg, M.D.
  Professor of Medicine, Division of Infectious Diseases
  Emory University School of Medicine
  Atlanta, GA