# Acknowledgments

The authors gratefully acknowledge Steve Gaynes at the University of Pennsylvania Health System, and the following individuals at ECRI Institute, for their contributions to this project: Michele Datko, James Davis, David Snyder, Gina Giradi, Luke Petosa, Joann Fontanarosa, Michael Phillips, Jennifer Maslin, Helen Dunn, Lydia Dharia, Katherine Donahue, and EPC Director Karen Schoelles.