# Appendix References

1 Amodio E, Dino C. Use of ATP bioluminescence for assessing the cleanliness of hospital surfaces: a review of the published literature (1990-2012). J Infect Public Health. Mar-Apr. 2014;7(2):92-8. [pmid: 24231159].
2 Mitchell BG, Wilson F, Dancer SJ, et al. Methods to evaluate environmental cleanliness in healthcare facilities. Healthc Infect. 2013;18(1):23-30.
3 Falagas ME, Thomaidis PC, Kotsantis IK, et al. Airborne hydrogen peroxide for disinfection of the hospital environment and infection control: a systematic review. J Hosp Infect. Jul. 2011;78(3):171-7. [pmid: 21392848].
4 Dettenkofer M, Wenzler S, Amthor S, et al. Does disinfection of environmental surfaces influence nosocomial infection rates? A systematic review. Am J Infect Control. Apr. 2004;32(2):84-9. [pmid: 15057199].
5 Best EL, Parnell P, Thirkell G, et al. Effectiveness of deep cleaning followed by hydrogen peroxide decontamination during high Clostridium difficile infection incidence. J Hosp Infect. Mar. 12. 2014;87(1):25-33. [pmid: 24746230].
6 Boyce JM, Havill NL, Guercia KA, et al. Evaluation of two organosilane products for sustained antimicrobial activity on high-touch surfaces in patient rooms. Am J Infect Control. Mar. 2014;42(3):326-8. [pmid: 24406256].
7 Haas JP, Menz J, Dusza S, et al. Implementation and impact of ultraviolet environmental disinfection in an acute care setting. Am J Infect Control. Jun. 2014;42(6):586-90. [pmid: 24837107].
8 Jinadatha C, Quezada R, Huber TW, et al. Evaluation of a pulsed-xenon ultraviolet room disinfection device for impact on contamination levels of methicillin-resistant Staphylococcus aureus. BMC Infect Dis. 2014;14(1):187. [pmid: 24708734].
9 Mitchell BG, Digney W, Locket P, et al. Controlling methicillin-resistant Staphylococcus aureus (MRSA) in a hospital and the role of hydrogen peroxide decontamination: an interrupted time series analysis. BMJ Open. 2014;4(4):e004522. [pmid: 24747791].
10 Sjoberg M, Eriksson M, Andersson J, et al. Transmission of Clostridium difficile spores in isolation room environments and through hospital beds. APMIS. Sep. 2014;122(9):800-3. [pmid: 24475890].
11 Stewart M, Bogusz A, Hunter J, et al. Evaluating use of neutral electrolyzed water for cleaning near-patient surfaces. Infect Control Hosp Epidemiol. 2014;35(12):1505-10. [pmid: 25419773].
12 Wiemken TL, Curran DR, Pacholski EB, et al. The value of ready-to-use disinfectant wipes: compliance, employee time, and costs. Am J Infect Control. Mar. 2014;42(3):329-30. [pmid: 24581022].
13 Anderson DJ, Gergen MF, Smathers E, et al. Decontamination of targeted pathogens from patient rooms using an automated ultraviolet-C-emitting device. Infect Control Hosp Epidemiol. May. 2013;34(5):466-71. [pmid: 23571362].
14 Boyce JM, Havill NL. Evaluation of a new hydrogen peroxide wipe disinfectant. Infect Control Hosp Epidemiol. May. 2013;34(5):521-3. [pmid: 23571371].
15 Friedman ND, Walton AL, Boyd S, et al. The effectiveness of a single-stage versus traditional three-staged protocol of hospital disinfection at eradicating vancomycin-resistant Enterococci from frequently touched surfaces. Am J Infect Control. Mar. 2013;41(3):227-31. [pmid: 22981721].
16 Gillespie E, Wilson J, Lovegrove A, et al. Environment cleaning without chemicals in clinical settings. Am J Infect Control. May. 2013;41(5):461-3. [pmid: 23177456].
17 Hess AS, Shardell M, Kristie Johnson J, et al. A randomized controlled trial of enhanced cleaning to reduce contamination of healthcare worker gowns and gloves with multidrug-resistant bacteria. Infect Control Hosp Epidemiol. May. 2013;34(5):487-93. [pmid: 23571365].
18 Levin J, Riley LS, Parrish C, et al. The effect of portable pulsed xenon ultraviolet light after terminal cleaning on hospital-associated Clostridium difficile infection in a community hospital. Am J Infect Control. Aug. 2013;41(8):746-8. [pmid: 23685092].
19 Mahida N, Vaughan N, Boswell T. First UK evaluation of an automated ultraviolet-C room decontamination device (Tru-D). J Hosp Infect. Aug. 2013;84(4):332-5. [pmid: 23846236].
20 Manian FA, Griesnauer S, Bryant A. Implementation of hospital-wide enhanced terminal cleaning of targeted patient rooms and its impact on endemic Clostridium difficile infection rates. Am J Infect Control. Jun. 2013;41(6):537-41. [pmid: 23219675].
21 Passaretti CL, Otter JA, Reich NG, et al. An evaluation of environmental decontamination with hydrogen peroxide vapor for reducing the risk of patient acquisition of multidrug-resistant organisms. Clin Infect Dis. 2013;56(1):27-35. [pmid: 23042972].
22 Salgado CD, Sepkowitz KA, John JF, et al. Copper surfaces reduce the rate of healthcare-acquired infections in the intensive care unit. Infect Control Hosp Epidemiol. May. 2013;34(5 Suppl):479-86. [pmid: 23571364].
23 Schmidt MG, Attaway HH, Fairey SE, et al. Copper continuously limits the concentration of bacteria resident on bed rails within the intensive care unit. Infect Control Hosp Epidemiol. May. 2013;34(5 Suppl):530-3. [pmid: 23571374].
24 Sigler V, Hensley S. Persistence of mixed staphylococci assemblages following disinfection of hospital room surfaces. J Hosp Infect. Mar. 2013;83(3):253-6. [pmid: 23374288].
25 Sitzlar B, Deshpande A, Fertelli D, et al. An environmental disinfection odyssey: Evaluation of sequential interventions to improve disinfection of Clostridium difficile isolation rooms. Infect Control Hosp Epidemiol. May. 2013;34(5):459-65. [pmid: 23571361].
26 Goldenberg SD, Patel A, Tucker D, et al. Lack of enhanced effect of a chlorine dioxide-based cleaning regimen on environmental contamination with Clostridium difficile spores. J Hosp Infect. Sep. 2012;82(1):64-7. [pmid: 22795136].
27 Grabsch EA, Mahony AA, Cameron DR, et al. Significant reduction in vancomycin-resistant enterococcus colonization and bacteraemia after introduction of a bleach-based cleaning-disinfection programme. J Hosp Infect. Dec. 2012;82(4):234-42. [pmid: 23103245].
28 Havill NL, Moore BA, Boyce JM. Comparison of the microbiological efficacy of hydrogen peroxide vapor and ultraviolet light processes for room decontamination. Infect Control Hosp Epidemiol. May. 2012;33(5):507-12. [pmid: 22476278].
29 Karpanen TJ, Casey AL, Lambert PA, et al. The antimicrobial efficacy of copper alloy furnishing in the clinical environment: a crossover study. Infect Control Hosp Epidemiol. Jan. 2012;33(1):3-9. [pmid: 22173515].
30 Kundrapu S, Sunkesula V, Jury LA, et al. Daily disinfection of high-touch surfaces in isolation rooms to reduce contamination of healthcare workers' hands. Infect Control Hosp Epidemiol. Oct. 2012;33(10):1039-42. [pmid: 22961024].
31 Schmidt MG, Anderson T, Attaway HH, et al. Patient environment microbial burden reduction: a pilot study comparison of 2 terminal cleaning methods. Am J Infect Control. Aug. 2012;40(6):559-61. [pmid: 21981792].
32 Schmidt MG, Attaway HH, Sharpe PA, et al. Sustained reduction of microbial burden on common hospital surfaces through introduction of copper. J Clin Microbiol. Jul. 2012;50(7):2217-23. [pmid: 22553242].
33 Boyce JM, Havill NL, Moore BA. Terminal decontamination of patient rooms using an automated mobile UV light unit. Infect Control Hosp Epidemiol. Aug. 2011;32(8):737-42. [pmid: 21768755].
34 Carter Y, Barry D. Tackling C difficile with environmental cleaning. Nurs Times. Sep. 13. 2011;107(36):22-6. [pmid: 21998939].
35 Chan HT, White P, Sheorey H, et al. Evaluation of the biological efficacy of hydrogen peroxide vapour decontamination in wards of an Australian hospital. J Hosp Infect. Oct. 2011;79(2):125-8. [pmid: 21824681].
36 Orenstein R, Aronhalt KC, McManus JE Jr, et al. A targeted strategy to wipe out Clostridium difficile. Infect Control Hosp Epidemiol. Nov. 2011;32(11):1137-9. [pmid: 22011546].
37 Sexton JD, Tanner BD, Maxwell SL, et al. Reduction in the microbial load on high-touch surfaces in hospital rooms by treatment with a portable saturated steam vapor disinfection system. Am J Infect Control. Oct. 2011;39(8):655-62. [pmid: 21641089].
38 Wilson AP, Smyth D, Moore G, et al. The impact of enhanced cleaning within the intensive care unit on contamination of the near-patient environment with hospital pathogens: a randomized crossover study in critical care units in two hospitals. Crit Care Med. Apr. 2011;39(4):651-8. [pmid: 21242793].
39 Alfa MJ, Lo E, Wald A, et al. Improved eradication of Clostridium difficile spores from toilets of hospitalized patients using an accelerated hydrogen peroxide as the cleaning agent. BMC Infect Dis. Sep. 15. 2010;10:268. [pmid: 20843348].
40 Casey AL, Adams D, Karpanen TJ, et al. Role of copper in reducing hospital environment contamination. J Hosp Infect. Jan. 2010;74(1):72-7. [pmid: 19931938].
41 Hacek DM, Ogle AM, Fisher A, et al. Significant impact of terminal room cleaning with bleach on reducing nosocomial Clostridium difficile. Am J Infect Control. Jun. 2010;38(5):350-3. [pmid: 20123150].
42 Hamilton D, Foster A, Ballantyne L, et al. Performance of ultramicrofibre cleaning technology with or without addition of a novel copper-based biocide. J Hosp Infect. Jan. 2010;74(1):62-71. [pmid: 19819583].
43 Hedin G, Rynback J, Lore B. Reduction of bacterial surface contamination in the hospital environment by application of a new product with persistent effect. J Hosp Infect. Jun. 2010;75(2):112-5. [pmid: 20381907].
44 Nerandzic MM, Cadnum JL, Pultz MJ, et al. Evaluation of an automated ultraviolet radiation device for decontamination of Clostridium difficile and other healthcare-associated pathogens in hospital rooms. BMC Infect Dis. 2010;10:197. [pmid: 20615229].
45 Rutala WA, Gergen MF, Weber DJ. Room decontamination with UV radiation. Infect Control Hosp Epidemiol. Oct. 2010;31(10):1025-9. [pmid: 20804377].
46 Andersen BM, Rasch M, Kvist J, et al. Floor cleaning: effect on bacteria and organic materials in hospital rooms. J Hosp Infect. Jan. 2009;71(1):57-65. [pmid: 19013671].
47 McMullen KM, Zack J, Coopersmith CM, et al. Use of hypochlorite solution to decrease rates of Clostridium difficile-associated diarrhea. Infect Control Hosp Epidemiol. Feb. 2007;28(2):205-7. [pmid: 17265404].
48 Whitaker J, Brown BS, Vidal S, et al. Designing a protocol that eliminates Clostridium difficile: a collaborative venture. Am J Infect Control. Jun. 2007;35(5):310-4. [pmid: 17577477].
49 De Lorenzi S, Finzi G, Parmiggiani R, et al. Comparison of floor sanitation methods. J Hosp Infect. Mar. 2006;62(3):346-8. [pmid: 16376456].
50 Wilcox MH, Fawley WN, Wigglesworth N, et al. Comparison of the effect of detergent versus hypochlorite cleaning on environmental contamination and incidence of Clostridium difficile infection. J Hosp Infect. Jun. 2003;54(2):109-14. [pmid: 12818583].
51 Byers KE, Durbin LJ, Simonton BM, et al. Disinfection of hospital rooms contaminated with vancomycin-resistant Enterococcus faecium. Infect Control Hosp Epidemiol. Apr. 1998;19(4):261-4. [pmid: 9605276].
52 Luick L, Thompson PA, Loock MH, et al. Diagnostic assessment of different environmental cleaning monitoring methods. Am J Infect Control. Aug. 2013;41(8):751-2. [pmid: 23380380].
53 Smith PW, Gibbs S, Sayles H, et al. Observations on hospital room contamination testing. Healthc Infect. 2013;18(1):10-3.
54 Snyder GM, Holyoak AD, Leary KE, et al. Effectiveness of visual inspection compared with non-microbiologic methods to determine the thoroughness of post-discharge cleaning. Antimicrob Resist Infect Control. 2013;2(1):26. [pmid: 24088298].
55 Mulvey D, Redding P, Robertson C, et al. Finding a benchmark for monitoring hospital cleanliness. J Hosp Infect. Jan. 2011;77(1):25-30. [pmid: 21129820].
56 Munoz-Price LS, Ariza-Heredia E, Adams S, et al. Use of UV powder for surveillance to improve environmental cleaning. Infect Control Hosp Epidemiol. Mar. 2011;32(3):283-5. [pmid: 21460514].
57 Carling PC, Parry MF, Bruno-Murtha LA, et al. Improving environmental hygiene in 27 intensive care units to decrease multidrug-resistant bacterial transmission. Crit Care Med. Apr. 2010;38(4):1054-9. [pmid: 20081531].
58 Alfa MJ, Dueck C, Olson N, et al. UV-visible marker confirms that environmental persistence of Clostridium difficile spores in toilets of patients with C. difficile-associated diarrhea is associated with lack of compliance with cleaning protocol. BMC Infect Dis. 2008;8:64. [pmid: 18474086].
59 Al Hamad A, Maxwell S. How clean is clean? Proposed methods for hospital cleaning assessment. J Hosp Infect. Dec. 2008;70(4):328-34. [pmid: 18848370].
60 Blue J, O'Neill C, Speziale P, et al. Use of a fluorescent chemical as a quality indicator for a hospital cleaning program. Can J Infect Control. 2008;23(4):216-9. [pmid: 19350998].
61 Carling PC, Parry MF, Von Beheren SM. Identifying opportunities to enhance environmental cleaning in 23 acute care hospitals. Infect Control Hosp Epidemiol. Jan. 2008;29(1):1-7. [pmid: 18171180].
62 Carling PC, Briggs J, Hylander D, et al. An evaluation of patient area cleaning in 3 hospitals using a novel targeting methodology. Am J Infect Control. Oct. 2006;34(8):513-9. [pmid: 17015157].
63 Malik RE, Cooper RA, Griffith CJ. Use of audit tools to evaluate the efficacy of cleaning systems in hospitals. Am J Infect Control. May. 2003;31(3):181-7. [pmid: 12734526].
64 Branch-Elliman W, Robillard E, McCarthy G, et al. Direct feedback with the ATP luminometer as a process improvement tool for terminal cleaning of patient rooms. Am J Infect Control. Feb. 2014;42(2):195-7. [pmid: 24485376].
65 Koll BS, Ruiz RE, Calfee DP, et al. Prevention of hospital-onset Clostridium difficile infection in the New York metropolitan region using a collaborative intervention model. Journal for healthcare quality: official publication of the National Association for Healthcare Quality. May-Jun. 2014;36(3):35-45. [pmid: 23294050].
66 Ramphal L, Suzuki S, McCracken IM, et al. Improving hospital staff compliance with environmental cleaning behavior. Proc (Bayl Univ Med Cent). Apr. 2014;27(2):88-91. [pmid: 24688183].
67 Rupp ME, Fitzgerald T, Sholtz L, et al. Maintain the gain: Program to sustain performance improvement in environmental cleaning. Infect Control Hosp Epidemiol. Jul. 2014;35(7):866-8. [pmid: 24915215].
68 Rupp ME, Huerta T, Cavalieri RJ, et al. Optimum outlier model for potential improvement of environmental cleaning and disinfection. Infection control and hospital epidemiology: the official journal of the Society of Hospital Epidemiologists of America. Jun. 2014;35(6):721-3. [pmid: 24799650].
69 Smith PW, Beam E, Sayles H, et al. Impact of adenosine triphosphate detection and feedback on hospital room cleaning. Infect Control Hosp Epidemiol. May. 2014;35(5):564-9. [pmid: 24709726].
70 Brakovich B, Bonham E, VanBrackle L. War on the spore: Clostridium difficile disease among patients in a long-term acute care hospital. Journal for healthcare quality: official publication of the National Association for Healthcare Quality. May-Jun. 2013;35(3):15-21. [pmid: 22304334].
71 Trajtman AN, Manickam K, Macrae M, et al. Continuing performance feedback and use of the ultraviolet visible marker to assess cleaning compliance in the healthcare environment. J Hosp Infect. Jun. 2013;84(2):166-72. [pmid: 23631799].
72 Ragan K, Khan A, Zeynalova N, et al. Use of audit and feedback with fluorescent targeting to achieve rapid improvements in room cleaning in the intensive care unit and ward settings. Am J Infect Control. Apr. 2012;40(3):284-6. [pmid: 21820762].
73 Datta R, Platt R, Yokoe DS, et al. Environmental cleaning intervention and risk of acquiring multidrug-resistant organisms from prior room occupants. Arch Intern Med. Mar. 28. 2011;171(6):491-4. [pmid: 21444840].
74 Murphy CL, MacBeth DA, Derrington P, et al. An assessment of high touch object cleaning thoroughness using a fluorescent marker in two Australian hospitals. Healthc Infect. 2011;16(4):156-63.
75 Hota B, Blom DW, Lyle EA, et al. Interventional evaluation of environmental contamination by vancomycin-resistant enterococci: failure of personnel, product, or procedure?. J Hosp Infect. Feb. 2009;71(2):123-31. [pmid: 19108932].
76 Po JL, Burke R, Sulis C, et al. Dangerous cows: an analysis of disinfection cleaning of computer keyboards on wheels. Am J Infect Control. Nov. 2009;37(9):778-80. [pmid: 19457585].
77 Carling PC, Parry MM, Rupp ME, et al. Improving cleaning of the environment surrounding patients in 36 acute care hospitals. Infect Control Hosp Epidemiol. Nov. 2008;29(11):1035-41. [pmid: 18851687].
78 Goodman ER, Platt R, Bass R, et al. Impact of an environmental cleaning intervention on the presence of methicillin-resistant Staphylococcus aureus and vancomycin-resistant enterococci on surfaces in intensive care unit rooms. Infect Control Hosp Epidemiol. Jul. 2008;29(7):593-9. [pmid: 18624666].
79 Eckstein BC, Adams DA, Eckstein EC, et al. Reduction of Clostridium Difficile and vancomycin-resistant Enterococcus contamination of environmental surfaces after an intervention to improve cleaning methods. BMC Infect Dis. Jun. 21. 2007;7:61. [pmid: 17584935].
80 Hayden MK, Bonten MJ, Blom DW, et al. Reduction in acquisition of vancomycin-resistant enterococcus after enforcement of routine environmental cleaning measures. Clin Infect Dis. Jun. 1. 2006;42(11):1552-60. [pmid: 16652312].
81 Surawicz CM, Brandt LJ, Binion DG, et al. Guidelines for diagnosis, treatment, and prevention of Clostridium difficile infections. Am J Gastroenterol. Apr. 2013;108(4):478-98. [pmid: 23439232].
82 Association for the Healthcare Environment. Practice guidance for healthcare environmental cleaning. 2nd edition. Chicago IL. American Hospital Association. 2010.
83 Collins A. Chapter 41. Preventing health care associated infections. Hughes RG, editor. Patient safety and quality: an evidence-based handbook for nurses. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Apr. 2008:547-75. http://www.ncbi.nlm.nih.gov/books/NBK2683/pdf/ch41.pdf.
84 Association for Professionals in Infection Control and Epidemiology (APIC). APIC position on mandatory public reporting of healthcare-associated infections. Washington (DC). Association for Professionals in Infection Control and Epidemiology (APIC). 2005. Mar. 14. 3 p. http://www.apic.org/Resource_/TinyMceFileManager/Position_Statements/MandRpt_posnPaoper_2005.pdf.
85 Greene L, Cain T, Khoury R, et al. APIC Position Paper: The importance of surveillance technologies in the prevention of healthcare-associated infections (HAIs). Washington (DC). Association for Professionals in Infection Control and Epidemiology (APIC). 2009. May. 29. 7 p. http://www.apic.org/Resource_/TinyMceFileManager/Position_Statements/Surveillance-Technologies-position-paper-2009.pdf.
86 Cardo D, Dennehy PH, Halverson P, et al. Moving toward elimination of healthcare-associated infections: a call to action. Am J Infect Control. Nov. 2010;38(9):671-5. [pmid: 21058460].
87 Friedman C, Curchoe R, Foster M, et al. APIC/CHICA-Canada infection prevention, control, and epidemiology: Professionals and practice standards. Washington (DC). Association for Professionals in Infection Control and Epidemiology (APIC). 2008. 5 p. http://www.apic.org/Resource_/TinyMceFileManager/Education/EPI-201-resources/EPI201_2012_resource_Leading_and_Managing_the_Infection_Prevention_Program.pdf.
88 Association for Professionals in Infection Control and Epidemiology, Inc. Guide to preventing clostridium difficile infections. Washington (DC). Association for Professionals in Infection Control and Epidemiology, Inc. 2013. Feb. 100 p. http://www.apic.org/Resource_/EliminationGuideForm/59397fc6-3f90-43d1-9325-e8be75d86888/File/2013CDiffFinal.pdf.
89 Association for Professionals in Infection Control and Epidemiology, Inc. Guide to the elimination of methicillin-resistant staphylococcus aureus (MRSA) transmission in hospital settings. 2nd edition. Washington (DC). Association for Professionals in Infection Control and Epidemiology, Inc. 2010. 65 p. http://www.apic.org/Resource_/EliminationGuideForm/631fcd91-8773-4067-9f85-ab2a5b157eab/File/MRSA-elimination-guide-2010.pdf.
90 Association for Professionals in Infection Control and Epidemiology, Inc. Guide to the elimination of methicillin-resistant staphylococcus aureus (MRSA) transmission in hospital settings. California supplement 2009. Washington (DC). Association for Professionals in Infection Control and Epidemiology, Inc. 2009. Apr. 3. 12 p. http://www.apic.org/Resource_/EliminationGuideForm/16c7a44f-55fe-4c7b-819a-b9c5907eca72/File/APIC-MRSA-California.pdf.
91 Association for Professionals in Infection Control and Epidemiology, Inc. Guide to the elimination of methicillin-resistant staphylococcus aureus (MRSA) in the long-term care facility. Washington (DC). Association for Professionals in Infection Control and Epidemiology, Inc. 2009. 74 p. http://www.apic.org/Resource_/EliminationGuideForm/08b12595-9f92-4a64-ad41-4afdd0088224/File/APIC-MRSA-in-Long-Term-Care.pdf.
92 Association of periOperative Registered Nurses (AORN). Recommended practices for environmental cleaning. In: 2014 perioperative standards and recommended practices. Denver (CO). Association of periOperative Registered Nurses (AORN). Sep. 2013:255-76. http://www.aornstandards.org/content/1/SEC18.body.
93 Allen G. Implementing AORN recommended practices for environmental cleaning. AORN J. May. 2014;99(5):570-82. [pmid: 24766919].
94 Stuart RL, Marshall C, McLaws ML, et al. ASID/AICA position statement - Infection control guidelines for patients with Clostridium difficile infection in healthcare settings. Healthc Infect. Mar. 2011;16(1):33-9.
95 Cheng AC, Ferguson JK, Richards MJ, et al. Australasian Society for Infectious Diseases guidelines for the diagnosis and treatment of Clostridium difficile infection. Med J Aust. Apr. 4. 2011;194(7):353-8. [pmid: 21470086].
96 Tomblyn M, Chiller T, Einsele H, et al. Guidelines for preventing infectious complications among hematopoietic cell transplantation recipients: a global perspective. Biol Blood Marrow Transplant. Oct. 2009;15(10):1143-238. [pmid: 19747629].
97 Rutala WA, Weber DJ, Healthcare Infection Control Practices Advisory Committee. Guidelinefor disinfection and sterilization in healthcare facilities, 2008. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2008. 158 p. http://www.cdc.gov/hicpac/Disinfection_Sterilization/17_00Recommendations.html.
98 Centers for Disease Control and Prevention (CDC). Antibiotic resistance threats in the United States, 2013. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2013. 114 p. http://www.cdc.gov/drugresistance/threat-report-2013/pdf/ar-threats-2013-508.pdf.
99 Guh A, Carling P, Environmental Evaluation Workgroup, Division of Healthcare Quality Promotion, National Center for Emerging, Zoonotic and Infectious Diseases. Options for evaluating environmental cleaning. [Toolkit]. 2010. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2010. Dec. 15 p. http://www.cdc.gov/HAI/pdfs/toolkits/Environ-Cleaning-Eval-Toolkit12-2-2010.pdf.
100 McKibben L, Horan T, Tokars JI, et al. Guidance on public reporting of healthcare-associated infections: Recommendations of the healthcare infection control practices advisory committee. Am J Infect Control. May. 2005;33(4):217-226. [pmid: 15877016].
101 Recommendations for preventing the spread of vancomycin resistance. Recommendations of the Hospital Infection Control Practices Advisory Committee (HICPAC). MMWR Recomm Rep. Sep. 22. 1995;44(RR-12):1-13. [pmid: 7639408].
102 Sehulster L, Chinn RY, CDC, et al. Guidelines for environmental infection control in health-care facilities. Recommendations of CDC and the Healthcare Infection Control Practices Advisory Committee (HICPAC). [Published errata appear in MMWR Recomm Rep 2003 Oct 24;52(42):1025-6]. MMWR Recomm Rep. Jun. 6. 2003;52(RR-10):1-42. [pmid: 12836624].
103 Siegel J, Rhinehart E, Jackson M, et al. Guideline for isolation precautions: preventing transmission of infectious agents in healthcare settings. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2007. Jun. 219 p. http://www.cdc.gov/ncidod/dhqp/pdf/guidelines/Isolation2007.pdf.
104 Siegel JD, Rhinehart E, Jackson M, et al. Management of multidrug-resistant organisms in healthcare settings. Atlanta (GA). Centers for Disease Control and Prevention. 2006. 74 p.
105 Umscheid C, Agarwal R, Brennan P. Updating the guideline methodology of the healthcare infection control practices advisory committee (HICPAC). Atlanta (GA). Centers for Disease Control and Prevention (CDC). 31 p. http://www.cdc.gov/hicpac/pdf/guidelines/2009-10-29HICPAC_GuidelineMethodsFINAL.pdf.
106 Vonberg RP, Kuijper EJ, Wilcox MH, et al. Infection control measures to limit the spread of Clostridium difficile. Clin Microbiol Infect. May. 2008;14:2-20. [pmid: 18412710].
107 European Society of Clinical Microbiology and Infectious Diseases. ESCMID consensus statements. Basel (Switzerland). European Society of Clinical Microbiology and Infectious Diseases. 2013. Feb. 14. https://www.escmid.org/escmid_library/medical_guidelines/escmid_consensus_statements/. 2014 Oct 07.
108 U.S. Environmental Protection Agency. Antimicrobial testing program - guideline methodology. Washington (DC). U.S. Environmental Protection Agency. 2014. Aug. 21. http://www.epa.gov/oppad001/antimicrobial-testing-program.html. 2014 Oct 07.
109 Bascetta CA. Health-care-associated infections in hospitals: Leadership needed from HHS to prioritize prevention practices and improve data on these infections: Report to the Chairman, Committee on Oversight and Government Reform, House of Representatives. Washington (DC). U.S. Government Accountability Office. 2008. Mar. 61 p. http://www.gao.gov/assets/280/274314.pdf.
110 Healthcare-Associated Infection Working Group of the Joint Public Policy Committee. Essentials of public reporting of HAIs, healthcare-associated infection working group of the Joint Public Policy Committee toolkit. 4 p. http://www.apic.org/Resource_/TinyMceFileManager/Position_Statements/Essentials_Tool_Kit.pdf.
111 Coia JE, Duckworth GJ, Edwards DI, et al. Guidelines for the control and prevention of meticillin-resistant Staphylococcus aureus (MRSA) in healthcare facilities. J Hosp Infect. May. 2006;63:1-44. [pmid: 16517005].
112 Cookson BD, Macrae MB, Barrett SP, et al. Guidelines for the control of glycopeptide-resistant enterococci in hospitals. J Hosp Infect. Jan. 2006;62(1):6-21. [pmid: 16310890].
113 Loveday HP, Wilson JA, Pratt RJ, et al. Epic3: National evidence-based guidelines for preventing healthcare-associated infections in NHS hospitals in England. J Hosp Infect. Jan. Suppl 1. 2014;86:S1-70. [pmid: 24330862].
114 National Clostridium difficile Standards Group: Report to the Department of Health. J Hosp Infect. Feb. Suppl 1. 2004;56:1-38. [pmid: 15129935].
115 Pratt RJ, Pellowe CM, Wilson JA, et al. epic2: National Evidence-Based Guidelines for Preventing Healthcare-Associated Infections in NHS Hospitals in England. J Hosp Infect. Feb. Suppl 1. 2007;65:S1-64. [pmid: 17307562].
116 Steer JA, Lamagni T, Healy B, et al. Guidelines for prevention and control of group A streptococcal infection in acute healthcare and maternity settings in the UK. J Infect. January. 2012;64(1):1-18. [pmid: 22120112].
117 Neely AN, Weber JM, Daviau P, et al. Computer equipment used in patient care within a multihospital system: Recommendations for cleaning and disinfection. Am J Infect Control. May. 2005;33(4):233-7. [pmid: 15877019].
118 Infection Prevention Society. Care setting process improvement tool: in & out patient areas/departments. Bathgate (Scotland). Infection Prevention Society. 44 p. http://www.ips.uk.net/files/8213/8044/9268/In_-_Out_Patient_Area_Departments_PIT.pdf.
119 Institute of Medicine (IOM). Initial national priorities for comparative effectiveness research. Washington (DC). National Academies Press. 2009. http://books.nap.edu/openbook.php?record_id=12648. 2010 Mar 03.
120 Damani N. Information resources in infection control. 6th edition. Armagh (Ireland). International Federation of Infection Control. 2009. 96 p. http://www.theific.org/pdf_files/resource_IFIC_Sept_2009.pdf.
121 Tietjen L, Bossemeyer D, McIntosh N. Infection prevention guidelines for healthcare facilities with limited resources. JHPIEGO Corporation. 2003. 419 p. http://pdf.usaid.gov/pdf_docs/PNACT433.pdf.
122 It's all the on the surface: establishing protocols for cleaning and disinfecting environmental surface areas. Environ Care News. Mar. 2010;13(3):6-11.
123 The Joint Commission. National patient safety goals effective January 1, 2014. Hospital accreditation program. Oakbrook Terrace (IL). The Joint Commission. 2013. 17 p. http://www.jointcommission.org/assets/1/6/HAP_NPSG_Chapter_2014.pdf.
124 Massachusetts Nurses Association. Exposure to environmental cleaning chemicals in healthcare settings. Canton (MA). Massachusetts Nurses Association. 2007. Oct. 01. http://www.massnurses.org/nursing-resources/position-statements/env-cleaning-chem. 2014 Oct 07.
125 Mehta Y, Gupta A, Todi S, et al. Guidelines for prevention of hospital acquired infections. Indian J Crit Care Med. Mar. 2014;18(3):149-63. [pmid: 24701065].
126 Prevention and control of healthcare-associated infections: quality improvement guide. PH36. London. National Institute for Health and Care Excellence (NICE). 2011. Nov. 01. http://publications.nice.org.uk/prevention-and-control-of-healthcare-associated-infections-ph36. 2013 Oct 01.
127 National Patient Safety Agency (NPSA). National specifications for cleanliness: primary medical and dental premises. London (UK). National Patient Safety Agency (NPSA). 2010. Aug. 44 p. http://www.nrls.npsa.nhs.uk/EasySiteWeb/getresource.axd?AssetID=75245%20.
128 National Patient Safety Agency. The revised healthcare cleaning manual. London. National Patient Safety Agency. 2009. Jun. 174 p. http://www.nrls.npsa.nhs.uk/EasySiteWeb/getresource.axd?AssetID=61814.
129 Provincial Infectious Diseases Advisory Committee (PIDAC). Routine practices and additional precautions in all health care settings. 3rd edition. Ottawa (Ontario). Public Health Ontario. 2012. 113 p. http://www.publichealthontario.ca/en/eRepository/RPAP_All_HealthCare_Settings_Eng2012.pdf.
130 Provincial Infectious Diseases Advisory Committee (PIDAC). Best practices for environmental cleaning for prevention and control of infections in all health care settings. 2nd edition. Ottawa (Ontario). Public Health Ontario. 2012. 183 p.
131 Provincial Infectious Diseases Advisory Committee (PIDAC). Review of literature for evidence-based best practices for VRE control. Ottawa (Ontario). Public Health Ontario. 2012. 24 p. http://www.publichealthontario.ca/en/eRepository/PIDAC-IPC_VRE_Evidence-based_Review_2012_Eng.pdf.
132 Public Health Agency of Canada. Clostridium difficile infection - infection prevention and control guidance for management in acute care settings. Ottawa (Ontario). Public Health Agency of Canada. 2013. Jan. 1. http://www.phac-aspc.gc.ca/nois-sinp/guide/c-dif-acs-esa/index-eng.php. 2014 Oct 7.
133 Public Health Agency of Canada. Routine practices and additional precautions for preventing the transmission of infection in healthcare settings. Ottawa (ON). Public Health Agency of Canada. 2012. 195 p. http://publications.gc.ca/collections/collection_2013/aspc-phac/HP40-83-2013-eng.pdf.
134 Royal College of Nursing. Creating a safe environment for care: defining the relationship between cleaning and nursing staff. London. Royal College of Nursing. 2013. 11 p. http://www.rcn.org.uk/__data/assets/pdf_file/0007/548719/004492.pdf.
135 Royal College of Nursing. Essential practice for infection prevention and control: guidance for nursing staff. London. Royal College of Nursing. 2012. 36 p. http://www.rcn.org.uk/__data/assets/pdf_file/0008/427832/004166.pdf.
136 Royal College of Nursing. Selection and use of disinfectant wipes. RCN guidance. London. Royal College of Nursing. 2011. 20 p. http://www.rcn.org.uk/__data/assets/pdf_file/0011/382538/003873.pdf.
137 Department of Health, Health Protection Agency. Clostridium difficile infection: how to deal with the problem. London (UK). Healthcare Associated Infection and Antimicrobial Resistance, Department of Health. 2008. Dec. 140 p.
138 Wilcox M. Updated guidance on the management and treatment of clostridium difficile infection. London. Public Health England. 2013. 29 p. https://www.gov.uk/government/uploads/system/uploads/attachment_data/file/321891/Clostridium_difficile_management_and_treatment.pdf.
139 Gebel J, Exner M, French G, et al. The role of surface disinfection in infection prevention. GMS Hyg Infect Control. 2013;8(1):Doc10. [pmid: 23967396].
140 Society for Healthcare Epidemiology of America (SHEA). Compendium of strategies to prevent healthcare-associated infections in acute care hospitals - overview page. Arlington (VA). Society for Healthcare Epidemiology of America (SHEA). 2014. http://www.shea-online.org/PriorityTopics/CompendiumofStrategiestoPreventHAIs.aspx. 2014 Oct 07.
141 Calfee DP, Salgado CD, Milstone AM, et al. Strategies to prevent Methicillin-resistant Staphylococcus aureus transmission and infection in acute care hospitals: 2014 update. Infect Control Hosp Epidemiol. Jul. 2014;35(7):772-96. [pmid: 24915205].
142 Dubberke ER, Carling P, Carrico R, et al. Strategies to prevent Clostridium difficile infections in acute care hospitals: 2014 Update. Infection control and hospital epidemiology: the official journal of the Society of Hospital Epidemiologists of America. Jun. 2014;35(6):628-45. [pmid: 24799639].
143 Calfee DP, Salgado CD, Classen D, et al. Strategies to prevent transmission of methicillin-resistant Staphylococcus aureus in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29:S62-80. [pmid: 18840090].
144 Dubberke ER, Gerding DN, Classen D, et al. Strategies to prevent Clostridium difficile infections in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29:S81-92. [pmid: 18840091].
145 Cohen SH, Gerding DN, Johnson S, et al. Clinical practice guidelines for Clostridium difficile infection in adults: 2010 update by the Society for Healthcare Epidemiology of America (SHEA) and the Infectious Diseases Society of America (IDSA). Infect Control Hosp Epidemiol. May. 2010;31(5):431-55. [pmid: 20307191].
146 Muto CA, Jernigan JA, Ostrowsky BE, et al. SHEA guideline for preventing nosocomial transmission of multidrug-resistant strains of Staphylococcus aureus and enterococcus. Infect Control Hosp Epidemiol. May. 2003;24(5):362-86. [pmid: 12785411].
147 U.S. Centers for Medicare and Medicaid Services (CMS). State operations manual: Appendix A - survey protocol, regulations and interpretive guidelines for hospitals. Baltimore (MD). U.S. Centers for Medicare and Medicaid Services (CMS). 2014. Jun. 6. 471 p. (CMS State Operations Manuals; http://www.cms.gov/Regulations-and-Guidance/Guidance/Manuals/downloads/som107ap_a_hospitals.pdf.
148 U.S. Department of Health and Human Services (HHS). National action plan to prevent health care-associated infections: road map to elimination. Washington (DC). U.S. Department of Health and Human Services (HHS). http://www.health.gov/hai/prevent_hai.asp#hai_plan. 2014 Oct 07.
149 Ducel G, Fabry J, Nicolle L, editors. Prevention of hospital-acquired infections: A practical guide. 2nd edition. Geneva (Switzerland). World Health Organization (WHO). 2002. 72 p. http://www.who.int/csr/resources/publications/drugresist/en/whocdscsreph200212.pdf?ua=1.