# Clinical Practice Guidelines and Ongoing Clinical Trials

Table D-1 Clinical practice guidelines

Organization | Reference | Country | Methods (Evidence-based or Consensus/narrative-based)
American College of Gastroenterology | Surawicz CM et al. Guidelines for diagnosis, treatment, and prevention of Clostridium difficile infections (http://gi.org/guideline/diagnosis-and-management-of-c-difficile-associated-diarrhea-and-colitis/). Am J Gastroenterol. 2013 Apr;108(4):478-98.^81^ | USA | Evidence-based
Association for the Healthcare Environment (AHE), formerly known as the American Society for Healthcare Environmental Services (ASHES) (part of the American Hospital Association) | Association for the Healthcare Environment. Practice guidance for healthcare environmental cleaning, 2nd edition (http://www.ahe.org/ahe/learn/tools_and_resources/publications.shtml%23.VCtqfGB0zIU). Chicago (IL): American Hospital Association; 2010.^82^ | USA | Evidence-based
Association for Healthcare Research and Quality (AHRQ) | Collins AS. Chapter 41. Preventing health care–associated infections (http://www.ncbi.nlm.nih.gov/books/NBK2683/). In: Hughes RG, editor. Patient safety and quality: An evidence-based handbook for nurses. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2008. p. 547-75. http://www.ncbi.nlm.nih.gov/books/NBK2683/pdf/ch41.pdf.83 | USA | Evidence-based
Association for Professionals in Infection Control and Epidemiology (APIC) | Association for Professionals in Infection Control and Epidemiology (APIC). APIC position on mandatory public reporting of HAIs (http://www.apic.org/Resource_/TinyMceFileManager/Position_Statements/MandRpt_posnPaoper_2005.pdf). Washington (DC): Association for Professionals in Infection Control and Epidemiology (APIC); 2005 Mar 14. 3 p. http://www.apic.org/Resource_/TinyMceFileManager/Position_Statements/MandRpt_posnPaoper_2005.pdf.84 | USA | Consensus/narrative
APIC | Greene LR et al. APIC Position Paper: The importance of surveillance technologies in the prevention of healthcare-associated infections (HAIs) (http://www.apic.org/Resource_/TinyMceFileManager/Position_Statements/Surveillance-Technologies-position-paper-2009.pdf). Washington (DC): 2009 May 29. 7 p.85 | USA | Evidence-based
APIC | Cardo D et al. Moving toward elimination of healthcare-associated infections: a call to action (http://www.apic.org/Resource_/TinyMceFileManager/Advocacy-PDFs/AJIC_Elimin.pdf). [White paper]. Am J Infect Control. 2010 Nov;38(9):671-5.^86^ “a joint white paper between APIC, Society for Healthcare Epidemiology of America (SHEA), Infectious Diseases Society of America (IDSA), Association of State and Territorial Health Officials, Council of State and Territorial Epidemiologists, Pediatric Infectious Diseases Society, and the Centers for Disease Control and Prevention.” | USA | Consensus/narrative
APIC | Friedman C et al. APIC/CHICA-Canada infection prevention, control, and epidemiology: Professionals and practice standards (http://www.apic.org/Resource_/TinyMceFileManager/Education/EPI-201-resources/EPI201_2012_resource_Leading_and_Managing_the_Infection_Prevention_Program.pdf). Washington (DC): Association for Professionals in Infection Control and Epidemiology (APIC); 2008. 5 p.87 | Canada | Consensus/narrative
APIC | Association for Professionals in Infection Control and Epidemiology, Inc. Guide to preventing Clostridium difficile infections (http://www.apic.org/Resource_/EliminationGuideForm/59397fc6-3f90-43d1-9325-e8be75d86888/File/2013CDiffFinal.pdf). Washington (DC): Association for Professionals in Infection Control and Epidemiology, Inc.; 2013 Feb. 100 p. http://www.apic.org/Resource_/EliminationGuideForm/59397fc6-3f90-43d1-9325-e8be75d86888/File/2013CDiffFinal.pdf.88 | USA | Consensus/narrative
APIC | Association for Professionals in Infection Control and Epidemiology, Inc. Guide to the elimination of methicillin-resistant Staphylococcus aureus (MRSA) transmission in hospital settings, 2nd edition (http://www.apic.org/Resource_/EliminationGuideForm/631fcd91-8773-4067-9f85-ab2a5b157eab/File/MRSA-elimination-guide-2010.pdf). Washington (DC): Association for Professionals in Infection Control and Epidemiology, Inc.; 2010. 65 p. http://www.apic.org/Resource_/EliminationGuideForm/631fcd91-8773-4067-9f85-ab2a5b157eab/File/MRSA-elimination-guide-2010.pdf.89 | USA | Evidence-based
APIC | Infection Control and Epidemiology, Inc. Guide to the elimination of methicillin-resistant Staphylococcus aureus (MRSA) transmission in hospital settings. California supplement (http://www.apic.org/Resource_/EliminationGuideForm/16c7a44f-55fe-4c7b-819a-b9c5907eca72/File/APIC-MRSA-California.pdf) 2009. Washington (DC): Association for Professionals in Infection Control and Epidemiology, Inc.; 2009 Apr 3. 12 p. http://www.apic.org/Resource_/EliminationGuideForm/16c7a44f-55fe-4c7b-819a-b9c5907eca72/File/APIC-MRSA-California.pdf.90 | USA | Consensus/narrative
APIC | Association for Professionals in Infection Control and Epidemiology, Inc. Guide to the elimination of methicillin-resistant Staphylococcus aureus (MRSA) in the long-term care facility (http://www.apic.org/Resource_/EliminationGuideForm/08b12595-9f92-4a64-ad41-4afdd0088224/File/APIC-MRSA-in-Long-Term-Care.pdf). Washington (DC): Association for Professionals in Infection Control and Epidemiology, Inc.; 2009. 74 p. http://www.apic.org/Resource_/EliminationGuideForm/08b12595-9f92-4a64-ad41-4afdd0088224/File/APIC-MRSA-in-Long-Term-Care.pdf.91 | USA | Evidence-based
Association of periOperative Registered Nurses (AORN) | Association of periOperative Registered Nurses (AORN). Recommended practices for environmental cleaning (http://www.aornstandards.org/content/1/SEC18.body). In: 2014 perioperative standards and recommended practices. Denver (CO): Association of perioperative Registered Nurses (AORN); 2013 Sep. p. 255-76.^92^ NGC summary. | USA | Evidence-based
AORN | Allen G. Implementing AORN recommended practices for environmental cleaning. AORN J. 2014 May;99(5):570-82. See: http://dx.doi.org/10.1016/j.aorn.2014.01.023.^93^ | USA | Evidence-based
Australasian Society for Infectious Diseases (ASID) | Stuart RL et al. ASID/AICA position statement: Infection control guidelines for patients with Clostridium difficile infection in healthcare settings (https://www.clinicalguidelines.gov.au/search.php?pageType=2&fldglrID=2129&). Healthc Infect. Mar 2011;16(1):33-9. http://dx.doi.org/10.1071/HI11011.^94^ | Australia | Consensus/narrative
ASID | Cheng AC et al. Australasian Society for Infectious Diseases guidelines for the diagnosis and treatment of Clostridium difficile infection (https://www.clinicalguidelines.gov.au/search.php?pageType=2&fldglrID=1897&). Med J Aust. 2011 Apr 4;194(7):353-8.^95^ | Australia | Evidence-based
Center for International Blood and Marrow Transplant Research (CIBMTR) | Tomblyn M et al. Guidelines for preventing infectious complications among hematopoietic cell transplantation recipients: A global perspective (http://www.cibmtr.org/ReferenceCenter/PubList/Pages/PublicationDetail.aspx?pubid=a02E0000004XrXgIAK&title=Guidelines%20for%20preventing%20infectious%20complications%20among%20hematopoietic%20cell%20transplantation%20recipients:%20a%20global%20perspective.). Biol Blood Marrow Transplant. 2009 Oct;15(10):1143-238.^96^ | Multinational | Evidence-based
Centers for Disease Control and Prevention (CDC), including the Healthcare Infection Control Practices Advisory Committee (HICPAC) | Rutala WA, Weber DJ, Healthcare Infection Control Practices Advisory Committee. Guideline for disinfection and sterilization in healthcare facilities (http://www.cdc.gov/hicpac/Disinfection_Sterilization/acknowledg.html), 2008. Atlanta (GA): Centers for Disease Control and Prevention; 2008. 158 p. http://www.cdc.gov/hicpac/Disinfection_Sterilization/17_00Recommendations.html.97 See also: Recommendations for disinfection and sterilization in health-care facilities (http://www.cdc.gov/hicpac/Disinfection_Sterilization/17_00Recommendations.html%23a8). | USA | Evidence-based
CDC, including HICPAC | Centers for Disease Control and Prevention (CDC). Antibiotic resistance threats in the United States, 2013. Atlanta (GA):Centers for Disease Control and Prevention (CDC); 2013 (http://www.cdc.gov/drugresistance/threat-report-2013/pdf/ar-threats-2013-508.pdf). 114 p. http://www.cdc.gov/drugresistance/threat-report-2013/pdf/ar-threats-2013-508.pdf.98 | USA | Evidence-based
CDC, including HICPAC | Guh A. Carling P, Environmental Evaluation Workgroup. Division of Healthcare Quality Promotion; National Center for Emerging, Zoonotic and Infectious Diseases. Options for evaluating environmental cleaning (http://www.cdc.gov/HAI/pdfs/toolkits/Environ-Cleaning-Eval-Toolkit12-2-2010.pdf). [Toolkit]. 2010. Atlanta (GA): Centers for Disease Control and Prevention (CDC); 2010 Dec.15 p. http://www.cdc.gov/HAI/pdfs/toolkits/Environ-Cleaning-Eval-Toolkit12-2-2010.pdf.99 Note: Additional resources (http://www.cdc.gov/HAI/prevent/prevention_tools.html%23eec). | USA | Consensus/narrative
CDC, including HICPAC | McGKibben L et al. Guidance on public reporting of healthcare-associated infections: Recommendations of the Healthcare Infection Control Practices Advisory Committee (http://www.cdc.gov/hicpac/pdf/PublicReportingGuide.pdf). Am J Infect Control. 2005 May;33(4):217-26.^100^ | USA | Consensus/narrative
CDC, including HICPAC | Recommendations for Preventing the Spread of Vancomycin Resistance Recommendations of the Hospital Infection Control Practices Advisory Committee (HICPAC) (http://www.cdc.gov/mmwr/preview/mmwrhtml/00039349.htm). MMWR Recomm Rep. 1995 Sep 22;44(RR-12):1-13.^101^ | USA | Consensus/narrative
CDC, including HICPAC | Sehulster L et al. Guidelines for environmental infection control in healthcare facilities (http://www.cdc.gov/MMWR/preview/MMWRhtml/rr5210a1.htm). Recommendations of CDC and the Healthcare Infection Control Practices Advisory Committee (HICPAC) [Published errata appear in MMWR Recomm Rep 2003 Oct 24;52(42):1025-6]. MMWR Recomm Rep. 2003 Jun 6;52(RR-10):1-42.^102^ | USA | Evidence-based
CDC, including HICPAC | Siegel J et al. Guideline for isolation precautions: preventing transmission of infectious agents in healthcare settings (http://www.cdc.gov/hicpac/pdf/isolation/isolation2007.pdf). Atlanta (GA): Centers for Disease Control and Prevention (CDC); 2007 Jun. 219 p.103 | USA | Evidence-based
CDC, including HICPAC | Siegel JD et al. Management of multidrug-resistant organisms in healthcare settings (http://www.cdc.gov/ncidod/dhqp/pdf/ar/mdroGuideline2006.pdf). 2006. 74 p.104 | USA | Evidence-based
CDC, including HICPAC | Umscheid C et al. Updating the Guideline Methodology of the Healthcare Infection Control Practices Advisory Committee (HICPAC) (http://www.cdc.gov/hicpac/guidelineMethod/guidelineMethod.html). Atlanta (GA): Centers for Disease Control and Prevention (CDC); 31 p. http://www.cdc.gov/hicpac/pdf/guidelines/2009-10-29HICPAC_GuidelineMethodsFINAL.pdf.105 Publication date not available. | USA | Evidence-based
European Centre for Disease Control and Prevention (ECDC) | Vonberg RP et al. Infection control measures to limit the spread of Clostridium difficile (http://ecdc.europa.eu/en/activities/sciadvice/_layouts/forms/Review_DispForm.aspx?List=a3216f4c-f040-4f51-9f77-a96046dbfd72&ID=634&Web=0be238ef-4498-4962-8826-2e082a1f1639). Clin Microbiol Infect. 2008 May;14:2-20. http://dx.doi.org/10.1111/j.1469-0691.2008.01992.x.106 | Europe | Evidence-based
European Society of Clinical Microbiology and Infectious Diseases (ESCMID) | European Society of Clinical Microbiology and Infectious Diseases. ESCMID consensus statements. Basel (Switzerland): European Society of Clinical Microbiology and Infectious Diseases; MRSA expert consensus documents (https://www.escmid.org/escmid_library/medical_guidelines/escmid_consensus_statements/), 2013 Feb 14. https://www.escmid.org/escmid_library/medical_guidelines/escmid_consensus_statements/. Accessed 2014 Oct 7.^107^ Note: See Humphreys H et al. Workshop 2 (https://www.escmid.org/fileadmin/src/media/PDFs/4ESCMID_Library/2Medical_Guidelines/other_guidelines/CMI_2009_15_2_120_Humphreys.pdf) for cleaning. | Europe | Consensus/narrative
Environmental Protection Agency (EPA) | U.S. Environmental Protection Agency. Antimicrobial testing program (http://www.epa.gov/oppad001/antimicrobial-testing-program.html) – guideline methodology. Washington (DC): U.S. Environmental Protection Agency; 2014 Aug 21. http://www.epa.gov/oppad001/antimicrobial-testing-program.html. Accessed 2014 Oct 7.^108^ Note: includes test results from August 2014. See also: The antimicrobial testing program. Hospital disinfectant and tuberculocidal products tested or pending testing (http://www.epa.gov/oppad001/atp-product-list.pdf). [List of products]. 2014 Aug 21. | USA | Evidence-based
Government Accounting Office (GAO) | Bascetta CA. Health-care-associated infections in hospitals: Leadership needed from HHS to prioritize prevention practices and improve data on these infections (http://www.gao.gov/products/GAO-08-283): Report to the Chairman, Committee on Oversight and Government Reform, House of Representatives. Washington (DC): U.S. Government Accountability Office; 2008 Mar. 61 p. http://www.gao.gov/assets/280/274314.pdf.109 | USA | Evidence-based
Healthcare-Associated Infection Working Group of the Joint Public Policy Committee. APIC, CDC, Council of State and Territorial Epidemiologists (CSTE), and Society for Healthcare Epidemiology of America (SHEA)] | Healthcare-Associated Infection Working Group of the Joint Public Policy Committee. Essentials of public reporting of HAIs, Healthcare-Associated Infection Working Group of the Joint Public Policy Committee toolkit (http://www.apic.org/Resource_/TinyMceFileManager/Position_Statements/Essentials_Tool_Kit.pdf). 4 p. http://www.apic.org/Resource_/TinyMceFileManager/Position_Statements/Essentials_Tool_Kit.pdf.110 Publication date not provided. | USA | Evidence-based
Healthcare Infection Society (UK) (formerly, the Hospital Infection Society) | Coia JE et al. Guidelines for the control and prevention of methicillin-resistant Staphylococcus aureus (MRSA) in healthcare facilities (http://www.his.org.uk/files/7113/7338/2934/MRSA_Guidelines_PDF.pdf). J Hosp Infect. 2006 May;63:1-44. http://dx.doi.org/10.1016/j.jhin.2005.10.014.^111^ | UK | Evidence-based
Healthcare Infection Society (UK) | Cookson BD et al. Guidelines for the control of glycopeptide-resistant enterococci in hospitals (http://www.his.org.uk/files/4113/7338/2928/GRE_guidelines.pdf). J Hosp Infect. 2006 Jan;62(1):6-21. http://dx.doi.org/10.1016/j.jhin.2005.02.016^112^ | UK | Evidence-based
Healthcare Infection Society (UK) | Loveday HP et al. epic3: national evidence-based guidelines for preventing healthcare-associated infections in NHS Hospitals in England (http://www.his.org.uk/files/3113/8693/4808/epic3_National_Evidence-Based_Guidelines_for_Preventing_HCAI_in_NHSE.pdf). J Hosp Infect. 2014 Jan;86. http://dx.doi.org/10.1016/S0195-6701(13)60012-2.^113^ | UK | Evidence-based
Healthcare Infection Society (UK) | National Clostridium difficile Standards Group: Report to the Department of Health (http://www.his.org.uk/files/9713/7338/2938/National_C._difficile_Standards_Group.pdf). J Hosp Infect. 2004 Feb;56 Suppl 1:1-38.^114^ | UK | Evidence-based
Healthcare Infection Society (UK) | Pratt RJ et al. epic2: National Evidence-Based Guidelines for Preventing Healthcare-Associated Infections in NHS Hospitals in England (http://www.his.org.uk/files/3813/7088/0820/4_epic2_National_Evidence-Based_Guidelines_for_Preventing_Healthcare-Associated_Infections_in_NHS_Hospitals_in_England_2007.pdf). J Hosp Infect. 2007 Feb;65. http://dx.doi.org/10.1016/S0195-6701(07)60002-4.^115^ | UK | Evidence-based
Healthcare Infection Society (UK) | Steer JA et al. Guidelines for prevention and control of group A streptococcal infection in acute healthcare and maternity settings in the UK (http://www.sciencedirect.com/science/article/pii/S0163445311005354). J Infect. 2012 Jan;64(1):1-18. http://dx.doi.org/10.1016/j.jinf.2011.11.001^116^ | UK | Evidence-based
Infection Control Working Group | Neely AN et al. Computer equipment used in patient care within a multihospital system: recommendations for cleaning and disinfection (http://www.sciencedirect.com/science/article/pii/S0196655305000684). Am J Infect Control. 2005 May;33(4):233-7. http://dx.doi.org/10.1016/j.ajic.2005.03.002.^117^ | USA | Evidence-based
Infection Prevention Society (IPS), formerly the Infection Control Nurses Association (ICNA) | Infection Prevention Society. Care setting process improvement tool in & out patient areas / departments (http://www.ips.uk.net/files/8213/8044/9268/In_-_Out_Patient_Area_Departments_PIT.pdf). Bathgate (Scotland): Infection Prevention Society; 44 p. http://www.ips.uk.net/files/8213/8044/9268/In_-_Out_Patient_Area_Departments_PIT.pdf.118 No publication date. | USA | Evidence-based
Institute of Medicine (IOM) | Institute of Medicine (IOM). Initial national priority for comparative effectiveness research (http://www.iom.edu/Reports/2009/ComparativeEffectivenessResearchPriorities.aspx). [book online]. Washington (DC): National Academies Press; 2009 Jan 1. [accessed 2010 Mar 3] [various].119 | USA | Evidence-based
International Federation for Infection Control (IFIC) | Damani N. Information resources in infection control (http://www.theific.org/pdf_files/resource_IFIC_Sept_2009.pdf), 6^th^ edition. Armagh (Ireland): International Federation of Infection Control; 2009. 96 p. http://www.theific.org/pdf_files/resource_IFIC_Sept_2009.pdf.120 | UK | Evidence-based
JHPIEGO Corporation, an affiliate of Johns Hopkins University | Tietjen L et al. Infection prevention guidelines for healthcare facilities with limited resources (http://pdf.usaid.gov/pdf_docs/PNACT433.pdf). JHPIEGO Corporation; 2003. 419 p. http://pdf.usaid.gov/pdf_docs/PNACT433.^121^ | USA | Evidence-based
Joint Commission | It’s all the on the surface: establishing protocols for cleaning and disinfecting environmental surface areas (http://www.jointcommission.org/assets/1/18/Its_All_on_the_Surface.pdf). Environ Care News. 2010 Mar;13(3):6-11. http://www.jointcommission.org/assets/1/18/Its_All_on_the_Surface.pdf.122 | USA | Evidence-based
Joint Commission | The Joint Commission. National patient safety goals effective January 1, 2014. Hospital accreditation program. Oakbrook Terrace (IL): The Joint Commission; 2013. 17 p. See: http://www.jointcommission.org/assets/1/6/HAP_NPSG_Chapter_2014.pdf.123 | USA | Evidence-based
Massachusetts Nurses Association | Massachusetts Nurses Association. Exposure to environmental cleaning chemicals in healthcare settings (http://www.massnurses.org/nursing-resources/position-statements/env-cleaning-chem). Canton (MA): Massachusetts Nurses Association; 2007 Oct 1. http://www.massnurses.org/nursing-resources/position-statements/env-cleaning-chem. Accessed 2014 Oct 7.^124^ | USA | Consensus/narrative
Mehta et al. | Mehta Y et al. Guidelines for prevention of hospital acquired infections (http://www.ncbi.nlm.nih.gov/pmc/articles/PMC3963198/). Indian J Crit Care Med. 2014 Mar;18(3):149–63. http://dx.doi.org/10.4103/0972-5229.128705.^125^ | India | Evidence-based
National Institute for Health and Care Excellence | Prevention and control of healthcare-associated infections: quality improvement guide (http://www.nice.org.uk/guidance/ph36). PH36. London (UK: National Institute for Health and Care Excellence (NICE); 2011 Nov 1. http://publications.nice.org.uk/prevention-and-control-of-healthcare-associated-infections-ph36. Accessed 2013 Oct 1.^126^ See: Quality improvement statement 5: Environmental cleanliness (http://www.nice.org.uk/guidance/ph36/chapter/quality-improvement-statement-5-environmental-cleanliness). | UK | Evidence-based
National Patient Safety Agency (NPSA) UK | National Patient Safety Agency (NPSA). National specifications for cleanliness: primary medical and dental premises (http://www.nrls.npsa.nhs.uk/EasySiteWeb/getresource.axd?AssetID=75245%20). London (UK): National Patient Safety Agency (NPSA); 2010 Aug. 44 p. http://www.nrls.npsa.nhs.uk/EasySiteWeb/getresource.axd?AssetID=75245%20.^127^ | UK | Consensus/narrative
NPSA | National Patient Safety Agency. The revised healthcare cleaning manual (http://www.nrls.npsa.nhs.uk/EasySiteWeb/getresource.axd?AssetID=61814). London: National Patient Safety Agency; 2009 Jun. 174 p. http://www.nrls.npsa.nhs.uk/EasySiteWeb/getresource.axd?AssetID=61814. 128 | UK | Evidence-based
Public Health Ontario, Provincial Infectious Diseases Advisory Committee (PIDAC) | Provincial Infectious Diseases Advisory Committee (PIDAC). Routine practices and additional precautions in all health care settings, 3rd edition (http://www.publichealthontario.ca/en/eRepository/RPAP_All_HealthCare_Settings_Eng2012.pdf). Ottawa (Ontario): Public Health Ontario; 2012 Nov.113 p. http://www.publichealthontario.ca/en/eRepository/RPAP_All_HealthCare_Settings_Eng2012.pdf.129 | Canada | Evidence-based
PIDAC | Provincial Infectious Diseases Advisory Committee (PIDAC). Best practices for environmental cleaning for prevention and control of Infections In all health care settings - 2nd edition (http://www.publichealthontario.ca/en/eRepository/Best_Practices_Environmental_Cleaning_2012.pdf). Ottawa (Ontario): Public Health Ontario; 2012 May.183 p.130 | Canada | Evidence-based
PIDAC | Provincial Infectious Diseases Advisory Committee (PIDAC). Review of literature for evidence-based best practices for VRE control (http://www.publichealthontario.ca/en/eRepository/PIDAC-IPC_VRE_Evidence-based_Review_2012_Eng.pdf). Ottawa (Ontario): Public Health Ontario; 2012. 24 p. http://www.publichealthontario.ca/en/eRepository/PIDAC-IPC_VRE_Evidence-based_Review_2012_Eng.pdf.131 | Canada | Evidence-based
Public Health Agency of Canada | Public Health Agency of Canada. Clostridium difficile infection - infection prevention and control guidance for management in acute care settings (http://www.phac-aspc.gc.ca/nois-sinp/guide/c-dif-acs-esa/index-eng.php). Ottawa (Ontario): Public Health Agency of Canada; 2013 Jan 1. http://www.phac-aspc.gc.ca/nois-sinp/guide/c-dif-acs-esa/index-eng.php. Accessed 2014 Oct 7.^132^ See the section: 14. Environmental cleaning (http://www.phac-aspc.gc.ca/nois-sinp/guide/c-dif-acs-esa/index-eng.php%23a14). | Canada | Evidence-based
Public Health Agency of Canada | Public Health Agency of Canada. Routine practices and additional precautions for preventing the transmission of infection in healthcare settings (http://www.phac-aspc.gc.ca/nois-sinp/guide/summary-sommaire/tihs-tims-eng.php). Ottawa (ON): Public Health Agency of Canada; 2012. 195 p. http://publications.gc.ca/collections/collection_2013/aspc-phac/HP40-83-2013-eng.pdf.133 | Canada | Evidence-based
Royal College of Nursing | Royal College of Nursing. Creating a safe environment for care: Defining the relationship between cleaning and nursing staff (http://www.rcn.org.uk/__data/assets/pdf_file/0007/548719/004492.pdf). London: Royal College of Nursing; 2013. 11 p. http://www.rcn.org.uk/__data/assets/pdf_file/0007/548719/004492.pdf.134 | UK | Consensus/narrative
Royal College of Nursing | Royal College of Nursing. Essential practice for infection prevention and control: Guidance for nursing staff (http://www.rcn.org.uk/__data/assets/pdf_file/0008/427832/004166.pdf). London: Royal College of Nursing; 2012. 36 p. http://www.rcn.org.uk/__data/assets/pdf_file/0008/427832/004166.pdf.135 Note: See sections: 3.2 Decontamination of equipment; and 3.3 Achieving and maintaining a clean clinical environment. | UK | Consensus/narrative
Royal College of Nursing | Royal College of Nursing. Selection and use of disinfectant wipes. RCN guidance (http://www.rcn.org.uk/__data/assets/pdf_file/0011/382538/003873.pdf). London: Royal College of Nursing; 2011. 20 p. http://www.rcn.org.uk/__data/assets/pdf_file/0011/382538/003873.pdf.136 | UK | Evidence-based
Public Health England/Department of Health | Department of Health, Health Protection Agency. Clostridium difficile infection: how to deal with the problem (https://www.gov.uk/government/publications/clostridium-difficile-infection-how-to-deal-with-the-problem). [Guidance]. London (UK): Healthcare Associated Infection and Antimicrobial Resistance, Department of Health; 2008 Dec.140 p.137 Note: See chapter 6: Prevention through environmental cleaning and disinfection. | UK | Evidence-based
Public Health England/Department of Health | Wilcox M. Updated guidance on the management and treatment of C. difficile infection (https://www.gov.uk/government/uploads/system/uploads/attachment_data/file/321891/Clostridium_difficile_management_and_treatment.pdf). London: Public Health England; 2013. 29 p. https://www.gov.uk/government/uploads/system/uploads/attachment_data/file/321891/Clostridium_difficile_management_and_treatment.pdf.138 | UK | Evidence-based
Rudolf Schuelke Foundation (Germany) | Gebel J et al. The role of surface disinfection in infection prevention (http://www.ncbi.nlm.nih.gov/pmc/articles/PMC3746601/pdf/HIC-08-10.pdf). [Consensus paper]. GMS Hyg Infect Control. 2013;8(1):Doc10. http://dx.doi.org/10.3205/dgkh000210.^139^ | Germany | Evidence-based
SHEA | Society for Healthcare Epidemiology of America (SHEA). Compendium of strategies to prevent healthcare-associated infections in acute care hospitals (http://www.shea-online.org/PriorityTopics/CompendiumofStrategiestoPreventHAIs.aspx) – overview page. Arlington (VA): Society for Healthcare Epidemiology of America (SHEA); 2014 Jan 1. http://www.shea-online.org/PriorityTopics/CompendiumofStrategiestoPreventHAIs.aspx. Accessed 2014 Oct 7.^140^ Note: This is an overview page. The recommendation sections related to this Technical Brief are listed in the next two documents. | USA | Evidence-based
SHEA | Calfee DP et al. Strategies to prevent methicillin-resistant staphylococcus aureus transmission and infection in acute care hospitals: 2014 update (http://www.jstor.org/stable/10.1086/676534). Infect Control Hosp Epidemiol. 2014 Jul;35(7):772-96. http://dx.doi.org/10.1086/676534.^141^ Note: from the 2014 Compendium. | USA | Evidence-based
SHEA | Dubberke ER et al. Strategies to prevent Clostridium difficile infections in acute care hospitals: 2014 update (http://www.jstor.org/stable/10.1086/676023). Infection control and hospital epidemiology: the official journal of the Society of Hospital Epidemiologists of America. 2014 Jun;35(6):628-45. http://dx.doi.org/10.1086/676023.^142^ Note: from the 2014 Compendium. | USA | Evidence-based
SHEA | Calfee DP et al. Strategies to Prevent Transmission of Methicillin-Resistant Staphylococcus aureus in Acute Care Hospitals (http://www.jstor.org/stable/10.1086/591061). Infect Control Hosp Epidemiol. 2008 Oct;29 Suppl 1:S62-80.^143^ Note: from the 2008 Compendium. | USA | Evidence-based
SHEA | Dubberke ER et al. Strategies to Prevent Clostridium difficile Infections in Acute Care Hospitals (http://www.jstor.org/stable/10.1086/591065). Infect Control Hosp Epidemiol. 2008 Oct;29 Suppl 1:S81-92.^144^ Note: from the 2008 Compendium. | USA | Evidence-based
SHEA | Cohen SH, et al. Clinical practice guidelines for Clostridium difficile infection in adults: 2010 Update by the Society for Healthcare Epidemiology of America (SHEA) and the Infectious Diseases Society of America (IDSA) (http://www.jstor.org/stable/10.1086/651706). Infect Control Hosp Epidemiol. 2010 May;31(5):431-55.^145^ | USA | Evidence-based
SHEA | Muto CA, et al. SHEA guideline for preventing nosocomial transmission of multidrug-resistant strains of Staphylococcus aureus and Enterococcus (http://www.shea-online.org/assets/files/position_papers/SHEA_MRSA_VRE.pdf). Infect Control Hosp Epidemiol. 2003 May;24(5):362-86. http://www.journals.uchicago.edu/doi/pdf/10.1086/502213.^146^ | USA | Evidence-based
U.S. Centers for Medicare and Medicaid Services (CMS) | U.S. Centers for Medicare and Medicaid Services (CMS). State operations manual: Appendix A—survey protocol, regulations and interpretive guidelines for hospitals (http://cms.hhs.gov/Regulations-and-Guidance/Guidance/Manuals/downloads/som107ap_a_hospitals.pdf). (Rev. 116, 06-06-14). Baltimore (MD): U.S. Centers for Medicare and Medicaid Services (CMS); 2014 Jun 6. 471 p. (CMS State Operations Manuals; http://www.cms.gov/Regulations-and-Guidance/Guidance/Manuals/downloads/som107ap_a_hospitals.pdf.147 Also may be of interest: Peasah SK et al. Medicare non-payment of hospital-acquired infections: infection rates three-years post-implementation (http://www.cms.gov/mmrr/Downloads/MMRR2013_003_03_a08.pdf). MMWR 2013;3(3). | USA | Consensus/narrative
U.S. Department of Health and Human Services (HHS) | U.S. Department of Health and Human Services (HHS). National action plan to prevent health care-associated infections: road map to elimination (http://www.health.gov/hai/prevent_hai.asp%23hai_plan). Washington (DC): U.S. Department of Health and Human Services (HHS). http://www.health.gov/hai/prevent_hai.asp#hai_plan. Accessed 2014 Oct 7.^148^ | USA | Evidence-based
World Health Organization (WHO) | Ducel G et al. Prevention of hospital-acquired infections: A practical guide. 2nd edition (http://www.who.int/csr/resources/publications/drugresist/WHO_CDS_CSR_EPH_2002_12/en/). Geneva (Switzerland): World Health Organization (WHO); 2002. 72 p. http://www.who.int/csr/resources/publications/drugresist/en/whocdscsreph200212.pdf?ua=1.^149^ | International | Evidence-based

Table D-2 Ongoing clinical trials

Clinicaltrials.gov Identifier | Sponsor | Study Design | Purpose | Start Date | Expected Completion Date | Estimated Enrollment | Primary Outcomes
NCT01579370 | Duke University | Randomized controlled | To determine the efficacy and feasibility of enhanced terminal room disinfection strategies to prevent HAIs and to determine the impact of environmental contamination on acquisition of multidrug-resistant pathogens among hospitalized patients. The intervention arm includes quaternary ammonium, bleach, quaternary ammonium and UV-C light, and bleach and UV-C light. | April 2012 | October 2014 | 50,000 | - Incidence rate of four target organisms (MRSA, VRE, C. difficile and MDR-Acinetobacter) among patients admitted to a study room; - Incidence rate of C. difficile among patients admitted to a study room
NCT01349192 | University of North Carolina, Chapel Hill | Randomized controlled | To determine whether an early eradication protocol is effective for eradicating MRSA and will provide an opportunity to obtain data regarding early clinical impact of new isolation of MRSA. The intervention arm includes an environmental decontamination component, including wiping down high-touch surfaces and medical equipment with surface disinfecting wipes daily for 21 days. | April 2011 | July 2015 | 80 | Percent of subjects in each arm with MRSA negative respiratory cultures at day 28
NCT02348346 | Dr. B. de Jong | Observational | To study the efficacy of MVX (titanium dioxide) on the microbial colonization of surfaces in the ICU. | March 2015 | December 2015 | Not Reported

ICU=intensive care unit; MRSA=methicillin-resistant Staphylococcus aureus; UV-C=ultraviolet-C; VRE=vancomycin-resistant enterococci.