# Clinical Evidence

Table C-1 Characteristics of systematic reviews

Citation | Objective | Search Strategy | Key Inclusion/Exclusion Criteria | Evidence Base | Interventions | Relevant Findings | Authors' Conclusions
Amodio and Dino 2014^1^ Use of ATP bioluminescence for assessing the cleanliness of hospital surfaces: A review of the published literature (1990–2012) | To systematically review the evidence on ATP bioluminescence | Searches were completed in PubMed and Scopus. Bibliographies of articles retrieved were also searched. 31 articles were considered for inclusion. | Articles were excluded for not pertaining to hospital surfaces, being an experimental design, or being published before 1990. | [underlined: Studies]: 12 studies published from 2000 to 2011 were included. Studies were conducted in the United Kingdom (8), United States (3), and Brazil (1) [underlined: Methods]: Surfaces were monitored after cleaning (4 studies), before and after cleaning (6 studies), or not reported (2) Pathogens were not described. | ATP devices were provided by 3M (5), Biotrace (4) and Hygiena (3). ATP thresholds (RLUs): 100: 2 (16.7%) 250: 5 (41.7%) 500: 4 (33.3%) Both 250 and 500: 1 (8.3%) | ATP measurements before cleaning (RLUs): Ranged from 0 to >500,000 ATP measurements after cleaning (RLUs): Ranged from 3 to 500,000 Failure rates before cleaning: 21.2% to 93.1% Failure rates after cleaning: 5.3% to 96.5% | “Although the use of ATP bioluminescence can be considered a quick and objective method for assessing hospital cleanliness, it appears to be still poorly standardized at both the national and international level.”
Mitchell et al. 2013^2^ Methods to evaluate environmental cleanliness in healthcare facilities | To describe monitoring methods used in environmental cleaning | Searches in MEDLINE, CINAHL, and PubMed for English language publications. A search of the gray literature included infection-control professional organization Web sites, Australian state government sites, and international guidelines. | Article addressing the efficacy of cleaning. Environmental cleanliness was categorized as process evaluation (visual inspection, use of fluorescent gel marker) and outcome evaluation (use of ATP or microbial cultures). | 124 articles were reviewed. Number of articles included not reported. | Visual inspection, fluorescent gel marker, ATP, microbial cultures | [underlined: Visual inspection (6 studies)]: Poor performance at identifying microbial load with 17%–93% more surfaces identified as “clean” than other assessment methods. [underlined: Fluorescent gel marker (7 studies)]: Frequently demonstrates a “lack of attention to high-risk surfaces in the near-patient zone.” [underlined: ATP]: ATP measurements have low specificity and sensitivity in detecting bacteria (1 study reported sensitivity/specificity of 57%). Factors that may affect ATP readings include residual detergents or disinfectants, including sodium hydrochlorite, eroded surfaces, plasticizers found in microfiber cloths or ammonium compounds found in laundry products. [underlined: Microbiological sampling]: Sampling to detect specific bacteria is “generally only recommended as part of an ongoing outbreak investigation, as a research study, or as part of a policy or process evaluation” since the process may take at least 2 days, requires expertise and lab access. | “Methods that evaluate cleaning performance are useful in assessing adherence to cleaning protocols, whereas methods that sample bio-burden provide a more relevant indication of infection risk. Fast, reproducible, cost-effective and reliable methods are needed for routine environmental cleaning evaluation in order to predict timely clinical risk.”
Falagas et al. 2011^3^ Airborne hydrogen peroxide for disinfection of the hospital environment and infection control: a systematic review | To review the effectiveness of airborne hydrogen peroxide in a clinical setting | Searches were completed in PubMed through December 2009. Bibliographies of relevant articles were also searched. | Included studies focused on the effectiveness of airborne hydrogen peroxide for reducing bacterial burden in the hospital setting and discussed pathogens naturally dispersed in this setting. | [underlined: Studies]: 10 studies were included. Pathogens addressed were MRSA (5), C. difficile (3), and multiple pathogens (2). [underlined: Settings]: Surgical wards, ward side rooms, single isolation rooms, multiple-bed ward bays, bathrooms, and other utility rooms. [underlined: High-touch areas]: Chairs, bed frames, control panels, bedside tables, remote controls, door handles, bed rails, telephones, sink taps, toilet seats, and sites handled by HCWs. [underlined: Pathogens]: MRSA, C. difficile, and others | [underlined: 7 studies] evaluated the BioQuell HPV system BioQuell Ltd., Andover, Hampshire, UK) [underlined: 3 studies] evaluated a hydrogen peroxide dry-mist system or “dry fog” (Gloster Sante Europe, Labège Cedex, France) | [underlined: Disinfection]: Contamination of sampled environmental sites Before cleaning (9 studies): 39.0% (range: 18.9%–81.0%) After terminal cleaning (6 studies): 28.3% (range: 11.9%–66.1%) After airborne hydrogen peroxide (10 studies): 2.2% (range: 0%–4.0%) [underlined: Infection Control] 1 study indicated eradication of MRSA in 1 20-bed surgical ward. Another study indicated significant reductions in C. difficile-associated disease in a 500-bed university-affiliated hospital. | “Data from several relevant studies indicate that disinfection of the hospital environment using airborne hydrogen peroxide in vapour or dry mist formulations, appears to provide additional benefits to currently used cleaning regimens, including inactivation of bacterial spores. Few studies have evaluated the use of airborne hydrogen peroxide disinfection as an adjunctive infection control measure in actual hospital practice. These limited relevant data are favourable, but further studies are needed to assess the effectiveness, safety, costs, and applicability of this novel method against other available cleaning methods.”
Dettenkofer et al. 2004^4^ Does disinfection of environmental surfaces influence nosocomial infection rates? | To review evidence for the effects of disinfection of environmental surfaces on hospital-acquired infection rates | Biological Abstracts/BIOSIS Previews (1980–1988/1989–2001); Cochrane Library (2001, Issue 4) Cochrane Clinical Trials Register; HECLINET: Health Care Literature Information Network (1969–2000); Medline (Ovid, 1966–2001); Science Citation Index (1991–1996); SwetScan (1997–2001); Web of Science (Science Citation Index Expanded, 1997–2001); EMBASE (1974–2001) and EMBASE alert; and Somed (1978–2000). General internet search was also undertaken. | Randomized controlled trials, cohort, case-control, and observational studies in English, German, French, Italian, and Spanish evaluating use of disinfectant or detergent for “inanimate surfaces” in health care settings were included. | 4 trials discussed impact of disinfectant vs. detergent on environmental surfaces. Dharan study compared NI rates in 2 different wings of a medical unit over 4 months. Danforth study used a crossover design to examine NI rates in 8 wards in a tertiary care teaching hospital over 3 months. Daschner study examined NI rates in ICU units over 12 months. Mayfield study examined use of 2 disinfectants on incidence of C. difficile in bone marrow transplant patients and patients in neurosurgical ICU and general medicine units. [underlined: High-touch areas]: Floors, furniture, bathrooms, toilets, and isolation rooms (Dharan) Floor (Danforth) Floor, patient care equipment, bedside tables, and bed frame (Daschner) Not described (Mayfield) [underlined: Pathogens]: MRSA, C. difficile, and others | [underlined: Dharan study] QAC, an active oxygen-based compound, and an alcohol solution [underlined: Danforth study] Disinfectant orthobenzyl parachlorophenol or detergent [underlined: Daschner study] Disinfectant (0.5% aldehyde) and detergent [underlined: Mayfield study] QAC or 1:10 hypochlorite solution | [underlined: Dharan study] Detergent only: Increase in bacterial surface counts QAC: No reduction in bacterial counts Active oxygen-based compound, the alcohol solution, and the dust-attracting floor mop: Significant reduction of bacterial counts. [underlined: Dharan, Danforth and Dashner studies] Occurrence of NI: No significant difference [underlined: Mayfield study]: CDAD incidence: Significant decrease in rates in bone marrow transplant patients, no reduction in patients on neurosurgical ICU or general medicine unit | “Disinfectants may pose a danger to staff, patients, and the environment and require special safety precautions. However, targeted disinfection of certain environmental surfaces is in certain instances an established component of hospital infection control. Given the complex, multifactorial nature of nosocomial infections, well-designed studies that systematically investigate the role of surface disinfection are required.”

ATP= adenosine triphosphate; CDAD=Clostridium difficile-associated diarrhea; C. difficile=Clostridium difficile; HCW=health care workers; HPV=hydrogen peroxide vapor; ICU=intensive care unit; MRSA=methicillin-resistant staphylococcus aureus; NI=nosocomial infection; QAC=quaternary ammonium compound; RLU=relative light unit.

Table C-2 Study characteristics of cleaning and disinfection studies

Author | Country | Study Design | General Cleaning Method | Study Length | Sample Size | Primary Setting | Pathogens | High-Touch Objects
Best et al. 2014^5,*^ | United Kingdom | Before/after | SC and AC | 20 weeks | 342 sites | Rehabilitation ward | C. difficile | Bed, curtain track, wall trunking, patient line boxes, tops of hoist rail
Boyce et al. 2014^6,*^ | United States | Before/after | EC | 4 weeks | 9 rooms 1,155 samples | Ward not specified | NR | Bed rail, remote control, toilet, tray table, telephone, doorknob, sink
Haas et al. 2014^7,**^ | United States | Before/after | AC | 2 years | 11,389 rooms | Ward not specified | C. difficile, MRSA, VRE | NR
Jinadatha et al. 2014^8,*^ | United States | Nonrandomized controlled | SC and AC | 2 months | 20 rooms (10 per arm) | Ward not specified | MRSA | Bed rail, call buttons, toilet, tray table, bathroom handrail
Mitchell et al. 2014^9^ | Australia | Interrupted time series | SC and AC | 6 years | 3,600 discharge cleans | Ward not specified | MRSA | Bed, vent, sink, console, chair, table, locker, mattress, pillow
Sjöberg et al. 2014^10,**^ | Sweden | Before/after | SC | 8 months | 10 rooms 150 samples | NR | C. difficile | Bed rail, call button, side table, toilet, doorknob
Stewart et al. 2014^11,*^ | United Kingdom | Before/after | SC | 4 months | 30 bed spaces | Elderly care | MRSA and MSSA | Bedside locker, left/right cotside, overbed table
Wiemken et al. 2014^12,*^ | United States | Randomized controlled | SC | 1 month | 9 rooms | Ward not specified | Hardy pathogens | Side table, toilet, sink
Anderson et al. 2013^13,*^ | United States | Prospective cohort | AC | 15 months | 27 rooms 142 samples | Ward not specified | Various pathogens including: C. difficile, VRE | Bed rail, floor, side table, toilet, chair arm, overbed table, sink counter
Boyce and Havill 2013^14,*^ | United States | Before/after | SC | NR | 72 rooms | Ward not specified | NR | Bed rail, remote control, toilet, tray table, phone, bedside panel, chair arm, blood pressure cuff, grab bar, and faucet handle
Friedman et al. 2013^15,**^ | Australia | Interrupted time series | SC | 10 days | 21 rooms 1,026 samples | Cancer ward | VRE | Floor, remote control, toilet, tray table, phone, locker drawer handle, bathroom tap
Gillespie et al. 2013^16^ | Australia | Before/after | SC | 3 months | 10 room 200 samples | General medical ward, residential aged care ward | C. difficile, VRE | Not specified
Hess et al. 2013^17,*^ | United States | Randomized controlled | SC | 10 months | 132 rooms 4,444 samples | ICU, surgical ward | Various pathogens including: MRSA | Bed rail, call button, light switch, tray table, bed control, desk, intravenous poles and infusion pumps, phone, room sink, supply cart, and others
Levin et al. 2013^18,**^ | United States | Interrupted time series | AC | 1 year | NR | ICU, contact precaution and other rooms | C. difficile | Patient room, including bathroom
Mahida et al. 2013^19,*^ | United Kingdom | Before/after | AC | NR | 6 rooms 32 locations | Intensive therapy unit, OR, and ward isolation room | Various pathogens including: MRSA, VRE | Not specified
Manian et al. 2013^20,**^ | United States | Before/after | SC and AC | 3 years | 870 rooms 1,123 rounds of cleaning | Ward not specified | C. difficile | Bed rail, call button, light switch, telephone, doorknob, sink
Passaretti et al. 2013^21,*^ | United States | Prospective cohort | SC and AC | 30 months | 1,039 rooms 6,607 patients | ICU | Various pathogens including: C. difficile, MRSA, VRE | Bed rail, computer keyboard, electronic monitoring equipment
Salgado et al. 2013^22^ | United States | Randomized controlled | SC and EC | 11 months | 16 rooms (8 copper, 8 standard) 614 patients (294 cared for in rooms with copper) | ICU | C. difficile, MRSA, VRE | Bed rail, overbed table, bed footboard, intravenous poles and arms of the visitors chair
Schmidt et al. 2013^23^ | United States | Nonrandomized controlled | AC and EC | 3 months | 75 beds | ICU | Various pathogens | Bed rail
Sigler and Hensley 2013^24^ | United States | Before/after | SC | NR | 10 rooms | Rooms occupied by patients with Staph infections (usually MRSA) | Various pathogens including: MRSA | Bed rail, call button, floor, tray table, sink, TV button, telephone
Sitzlar et al. 2013^25^ | United States | Interrupted time series | SC and AC | 21 months | NR | General medical ward, surgical ward | C. difficile | Bed rail, call button, toilet, tray table, telephone
Goldenberg et al. 2012^26^ | United Kingdom | Before/after | SC | 4 months | 13 wards | General medical ward, surgical ward, plastic surgery, orthopedics, elderly care, acute admissions | C. difficile | Bed rail, call button, floor, remote control, toilet, telephone, locker, chair, sluice room, side room, mop bucket, and others
Grabsch et al. 2012^27^ | Australia | Interrupted time series | SC | 24 months | NR | ICU, cancer ward, liver transplant, renal | VRE | Call button, curtain, locker handle, chair, chart, supplies trolley, phone
Havill et al. 2012^28,*^ | United States | Non-randomized controlled | AC | NR | 15 rooms | Ward not specified | Various pathogens including: C. difficile | Bed rail, remote control, toilet, tray table
Karpanen et al. 2012^29,*^ | United Kingdom | Crossover | EC | 24 weeks | 19 rooms | General medical ward | C. difficile, MRSA, VRE | 14 HTOs including toilet seat, grab rail and door handle
Kundrapu et al. 2012^30,*^ | United States | Randomized controlled | SC | NR | 70 patients | Ward not specified | C. difficile, MRSA | Bed rail Call button Side table Toilet telephone, chair, wall mounted vital signs equipment, IV medication stand, door knobs and handles,
Schmidt et al. 2012^31,*^ | United States | Randomized controlled | SC and AC | 3 months | NR | Ward not specified | Various pathogens including: MRSA, VRE | Bed rail
Schmidt et al. 2012^32^ | United States | Before/after | SC and EC | 43 months | 1,587 rooms 9,522 objects | ICU | C. difficile, MRSA, VRE | Bed rail, call button, tray table, intravenous stand, visitor chair, computer mouse, data input device
Boyce et al. 2011^33,*^ | United States | Before/after | AC | NR | 25 rooms | Ward not specified | C. difficile | Bed rail, toilet, tray table, television remote
Carter and Barry 2011^34,**^ | United Kingdom | Before/after | SC | 18 months | NR | NR | C. difficile | Light switch, toilet, furniture, bed frame, intravenous pump
Chan et al. 2011^35,*^ | Australia | Nonrandomized controlled | SC and AC | NR | NR | Ward not specified | VRE | Call button, side, toilet, arm rest, cotside
Orenstein et al. 2011^36,*^ | United States | Before/after | SC | 2 years | NR | General medical ward | C. difficile | Not specified
Sexton et al. 2011^37,*^ | United States | Before/after | Steam vapor | 2 days | 8 rooms | Long-term care wing | Various pathogens including: C. difficile, MRSA | Bed rail, side table, guest chair arm, sink, door push panel
Wilson et al. 2011^38,*^ | United Kingdom | Randomized crossover | SC and “enhanced cleaning” | 1 year | 20,736 samples 1,152 bed days | ICU | Various pathogens including: C. difficile, MRSA, VRE | Bed rail, drawer handle, chart, keyboard, syringe driver, nurses hand, monitor
Alfa et al. 2010^39,*^ | Canada | Before/after | SC | 19 months | 243 patients 714 samples | Ward not specified | C. difficile | Toilet
Casey et al. 2010^40,*^ | United Kingdom | Non-randomized controlled | EC | 10 weeks | NR | General medical ward, common area | Various pathogens including: C. difficile, MRSA, VRE | Toilet, sink, door push plate
Hacek et al. 2010^41,**^ | United States | Before/after | SC | 3 years | All rooms occupied by patients with C. difficile in 3 hospitals; # not specified | Ward not specified | C. difficile | Bed, bed rail, bed control, floor, side table, toilet, tray table, doorknob, sink, wall
Hamilton et al. 2010^42,*^ | United Kingdom | Non-randomized controlled | SC | 7 weeks | NR | Ward not specified | NR | Bed, floor, tray table
Hedin et al. 2010^43^ | Sweden | Non-randomized controlled | EC | 3 weeks | 12 rooms 36 samples | infectious disease ward | Various pathogens including: MRSA | Side table
Nerandzic et al. 2010^44^ | United States | Before/after | AC | NR | 66 rooms, 261 sites | Ward not specified | C. difficile, MRSA, VRE | Call light, bedside table, telephone and bed rail
Rutala et al. 2010^45,*^ | United States | Before/after | AC | 8 months | 8 rooms | Ward not specified | C. difficile, MRSA | Bed rail, floor
Andersen et al. 2009^46^ | Norway | Non-randomized controlled | SC | NR | 4 rooms 192 samples | Geriatric ward | Various pathogens including: C. difficile, MRSA, VRE | Floor
McMullen et al. 2007^47,**^ | United States | Non-randomized controlled | SC | 2.5 years | Entire medical and surgical ICUs included for 2 1/2 years | ICU, common area | C. difficile | Not specified
Whitaker et al. 2007^48,**^ | United States | Before/after | SC | 2 years | NR | Ward not specified | C. difficile | “Every lateral surface”
De Lorenzi et al. 2006^49,**^ | Italy | Non-randomized controlled | Mopping methods | 5 days | 2 rooms | Surgical ward | NR | Floor
Wilcox et al. 2003^50^ | United Kingdom | Non-randomized controlled | SC | 2 years | 1,128 samples | 2 “elderly medicine wards” | C. difficile | Bed rail, floor, toilet
Byers et al. 1998^51,***^ | United States | Before/after | SC | NR | 10 conventional rooms, 4 bucket method; 376 conventional samples, 135 bucket samples | Ward not specified | VRE | Bed rail, floor, side table, intravenous pole, phone, blood pressure cuff, wall panel control

* Manufacturer-funded (i.e., sponsoring institution reported receiving equipment and/or monetary funding from the manufacturer for execution of the study.)

** Funding not reported

*** Described an outbreak situation

AC=automated cleaning; C. difficile=Clostridium difficile; EC=enhanced coating; ICU=intensive care unit; MRSA=methicillin-resistant staphylococcus aureus; MSSA=methicillin-susceptible staphylococcus aureus; NR=not reported; OR=operating room; SC=surface cleaning; VRE=vancomycin-resistant enterococci.

Table C-3 Methods of cleaning and disinfection reported in studies^*^

Author | Cleaning Method | Monitoring Method | Implementation Tools
Best et al. 2014^5^ | Chlor-Clean disinfectant (Gues Medical Ltd., Aylesford, UK), Deprox hydrogen peroxide decontamination unit (Hygiene Solutions, Kings Lynn, UK) | Sponge/wipe cultures | NR
Boyce et al. 2014^6^ | Organosilane antimicrobial coatings (Eco Antimicrobial; Micro-Texpur, Conover, NC; and Bio-Protect AM500; PureShield, Inc., Jupiter, FL) | Agar slide cultures | NR
Haas et al. 2014^7^ | Pulsed xenon ultraviolet light (PPX-UV) (Xenex Corp., Austin, TX) | NR | NR
Jinadatha et al. 2014^8^ | Dispatch bleach solution, PPX-UV (Xenex Healthcare Services, San Antonio, TX) | Contact plates | NR
Mitchell et al. 2014^9^ | ph neutral detergent, dry hydrogen vapor room decontamination system (Nocospray, EquipMed, North Ryde, New South Wales, Australia) | Swab cultures | Competency-based training, staff feedback
Sjöberg et al. 2014^10^ | Potassium monopersulfate-based disinfectant Virkon (Antec International Ltd., Sudbury, UK) | NR | NR
Stewart et al. 2014^11^ | Electrolyzed water (Salvesan; Aqualution) | Dip slides | NR
Wiemken et al. 2014^12^ | Sodium hypochlorite cleaner/disinfectant solutions (ready-to-use wipes versus bucket method) | Fluorescent/UV markers | Employee productivity and compliance
Anderson et al. 2013^13^ | Ultraviolet-C (UV-C) emitter (Tru-D Smart UVC, Lumalier, Memphis, TN). | Contact plates | NR
Boyce and Havill 2013^14^ | Hydrogen peroxide disinfectant wipe (Activated Hydrogen Peroxide; Clorox Healthcare) | ATP bioluminescence, Agar contact plates for aerobic bacteria | NR
Friedman et al. 2013^15^ | Benzalkonium chloride-based product, Viraclean (Whiteley Industrial PTY LTD, Tomago, New South Wales, Australia) or disposable V-wipes | Swab cultures | Audits
Gillespie et al. 2013^16^ | Ultramicrofiber cloths^**^ (Johnson Diversey, Racine, WI) and steam (UMF/steam) technology | ATP bioluminescence, Fluorescent/UV markers, visual observation, swab cultures | Education, infection control sessions for cleaning staff, feedback from staff focus groups
Hess et al. 2013^17^ | Enhanced cleaning (cleaning targeted at frequently touched, frequently contaminated surfaces), with wipes saturated with quaternary ammonium | Fluorescent/UV markers, swab cultures | NR
Levin et al. 2013^18^ | PPX-UV device (Xenex Healthcare Services, San Antonio, TX) | NR | NR
Mahida et al. 2013^19^ | UV-C (Tru-D™; manufacturer not specified) | Surface contact plates and seeded petri dishes | NR
Manian et al. 2013^20^ | Bleach, hydrogen peroxide vapor decontamination (Bioquell, Andover, UK) | NR | NR
Passaretti et al. 2013^21^ | Quaternary ammonium compound (QAC; 3M, St Paul, Minnesota). Oxivir disinfectant (Johnson Diversity, Sturtevant, Wisconsin), and hydrogen peroxide vapor (Bioquell, Horsham, PA) | Swab cultures | NR
Salgado et al. 2013^22^ | Virex 256 (Johnson-Diversey), Dispatch (Caltech Industries), and Cavicide (Metrex); copper-enhanced surfaces | NR | NR
Schmidt et al. 2013^23^ | Virex II 256 dispensed from an automated dilution system (Use Solution, Johnson Diversey); copper enhanced surfaces | Wipes | NR
Sigler and Hensley 2013^24^ | QAC, microfiber cloths^**^ and mops | Visual observation | NR
Sitzlar et al. 2013^25^ | Clorox Germicidal Wipes, UV-C (Tru-D, Lumalier, Memphis, TN) | ATP bioluminescence, fluorescent/UV markers | Education and feedback to staff (monthly meeting, small group meetings, and for individuals); a dedicated daily disinfection team and implementation of a process requiring supervisory assessment and clearance of terminally cleaned CDI rooms
Goldenberg et al. 2012^26^ | A chlorine dioxide-based disinfectant, Difficil-S (Clinimax Ltd, Bury St Edmunds, UK). | Swab cultures | Training on preparation, use, and storage of the product; monthly environmental cleaning audits
Grabsch et al. 2012^27^ | Bleach-Clean, a bleach-based disinfection program | Swab cultures | Employment of cleaning supervisors; new verbal and written training program for cleaners; new system of performance appraisal and benchmarking; regular monthly screening of standardized sites
Havill et al. 2012^28^ | Hydrogen peroxide vapor (Bioquell, Horsham, PA) vs. UV-C (Tru-D, Lumalier, Memphis, TN) | Agar slide cultures | NR
Karpanen et al. 2012^29^ | Copper surfaces | Swab cultures | NR
Kundrapu et al. 2012^30^ | Daily cleaning of high-touch surfaces vs. cleaning only when soiled | Glove and hand plate cultures | NR
Schmidt et al. 2012^31^ | Virex 256 soaked on a washcloth, QAC as a microdroplet from the PureMist system (PureCart Systems, Green Bay, WI) | Agar slide cultures | NR
Schmidt et al. 2012^32^ | Virex 256 (Johnson-Diversey), Dispatch (Caltech Industries), and Cavicide (Metrex); copper-enhanced surfaces | Swab cultures | NR
Boyce et al. 2011^33^ | Mobile UV-C (Tru-D; Lumalier, Memphis, TN) | Contact plates | NR
Carter and Barry 2011^34^ | Peracetic acid-releasing sporicidal wipes | NR | Training, infection prevention, and control awareness days, ward visits by nurses included feedback with staff; flyers and newsletters were disseminated.
Chan et al. 2011^35^ | A neutral detergent (HC90, Agar Cleaning Systems, Preston, Victoria, Australia) two hypochlorite-based products Bleach (Agar Cleaning Systems, Preston, Victoria, Australia) and Det-Sol 500 (Eucalip Bio Chemicals, Dandenong South, Victoria, Australia) ; and hydrogen peroxide vapour (Nocospray, EquipMed, North Ryde, NSW, Australia) | Contact plates | NR
Orenstein et al. 2011^36^ | Germicidal bleach wipes | ATP bioluminescence, visual observation | NR
Sexton et al. 2011^37^ | Steam vapor (VaporJet PC 2400 Steam Vapor System with the TANCS component from Advanced Vapor Technologies (Seattle, WA).) | Wipe/swatch cultures | NR
Wilson et al. 2011^38^ | Detergent, alcohol spray, Actichlor Plus (Ecolab, Swindon, UK), steam cleaning, enhanced cleaning using microfiber cloths (Johnson Diversey Northampton, Northants, UK) | Agar slide cultures, contact plates, hand cultures | NR
Alfa et al. 2010^39^ | Oxivir accelerated hydrogen peroxide (Diversey, Sturtevant, WI) vs. PerDiem stabilized hydrogen peroxide (SHP) (Diversey) | Fluorescent/UV markers, contact plates | NR
Casey et al. 2010^40^ | Copper surfaces | NR | NR
Hacek et al. 2010^41^ | Bleach | NR | NR
Hamilton et al. 2010^42^ | Ultramicrofiber cloths and mops, copper biocide | Agar slide cultures | NR
Hedin et al. 2010^43^ | “Appeartex,” an antimicrobial coating (Appeartex AB, Göteborg, Sweden) | Swab cultures, Agar slide cultures | NR
Nerandzic et al. 2010^44^ | UV-C light emitting (Tru-D; Lumalier Corporation, Memphis, TN) | Swab cultures | NR
Rutala et al. 2010^45^ | UV-C light emitting (Tru-D; Lumalier Corporation, Memphis, TN) | Agar slide cultures | NR
Andersen et al. 2009^46^ | 4 floor-mopping methods (dry, spray, moist and wet) | ATP bioluminescence, contact plates | NR
McMullen et al. 2007^47^ | Bleach | NR | NR
Whitaker et al. 2007^48^ | Bleach | NR | Education for staff, patients, and visitors
De Lorenzi et al. 2006^49^ | Floor cleaning by dry, then wet mopping versus wet, then dry mopping | Agar slide cultures | NR
Wilcox et al. 2003^50^ | Bleach | Swab cultures | NR
Byers et al. 1998^51^ | Quaternary ammonium spray vs. bucket method (drenching surface) | Swab cultures | NR

* None of the studies discussed patient safety culture or sustainability of programs. For external factors, Mitchell et al. 2014^9^ discussed the external quality control process undertaken by the manufacturer.

** The linear density of microfibers and ultramicrofibers are less than one denier per thread and less than 0.5 denier per thread, respectively. A strand of silk is approximately one denier.

ATP=adenosine triphosphate; CDI=Clostridium difficile infection; HT=high touch; IPC=infection protection and control; NR=not reported; UV=ultraviolet; UV-C=ultraviolet light.

Table C-4 Outcomes and conclusions of cleaning/disinfection studies

Author | Primary Outcome | Secondary Outcome of Interest | Authors Conclusions
Best et al. 2014^5^ | Sites positive for C. diff^a^ CDI incidence^b^ | C. diff ribotypes | “HPD, after deep cleaning with a detergent/chlorine agent, was highly effective for removing environmental C. difficile contamination. Long-term follow-up demonstrated that a CDI-symptomatic patient can rapidly recontaminate the immediate environment. Determining a role for HPD should include long-term cost-effectiveness evaluations.”
Boyce et al. 2014^6^ | Mean ACC a | NR | “Cultures of surfaces obtained before daily cleaning with a quaternary ammonium disinfectant showed no significant residual antimicrobial activity of the organosilane products, although a modest reduction could not be excluded.”
Haas et al. 2014^7^ | Incidence rate of HAIs^b^ | NR | “During the time period UVD was in use, there was a significant decrease in overall hospital-acquired MDRO plus CD in spite of missing 24% of opportunities to disinfect contact precautions rooms. This technology was feasible to use in our acute care setting and appeared to have a beneficial effect.”
Jinadatha et al. 2014^8^ | ACC, a total MRSA^b^ | Individual surface counts, cleaning time in minutes | “PPX-UV technology appears to be superior to manual cleaning alone for MRSA and HPC. Incorporating 15 minutes of PPX-UV exposure time to current hospital room cleaning practice can improve the overall cleanliness of patient rooms with respect to selected micro-organisms.”
Mitchell et al. 2014^9^ | Incidence of MRSA^b^ | NR | “Use of HP disinfection led to a decrease in residual MRSA contamination in patient rooms compared with detergent. It may also have encouraged the reduction in patient MRSA acquisition despite several confounders including staff feedback on terminal cleaning, additional MRSA screening and quicker laboratory methods. Infection control is best served by concurrent interventions targeting both the patient and healthcare environment.”
Sjöberg et al. 2014^10^ | Sites positive for culture a | NR | “We demonstrated a moderate spread of CD spores to the environment despite routine cleaning procedures involving Vikron.”
Stewart et al. 2014^11^ | CFU a | Recontamination | “Cleaning with electrolyzed water reduced ACC and staphylococci on surfaces beside patients. ACC remained below precleaning levels at 48 hours, but MSSA/MRSA counts exceeded original levels at 24 hours after cleaning. Although disinfectant cleaning quickly reduces bioburden, additional investigation is required to clarify the reasons for rebound contamination of pathogens at near patient sites.”
Wiemken et al.12 | Compliance with room protocol a | Time needed to clean | “In conclusion, this study supports the use of RTU CD wipes over the traditional bucket method. Enhancing environmental processes may reduce the environmental bioburden, leading to reductions in HAIs because of environmentally hardy pathogens.”
Anderson et al. 2013^13^ | Total number of CFU, median number of CFUs per sample a | NR | “Our data confirm that automated UV-C-emitting devices can decrease the bioburden of important pathogens in real-world settings such as hospital rooms.”
Boyce and Havill 2013^14^ | CFU a | RLU, adverse effects | “The activated hydrogen peroxide wipe product evaluated in our study proved to be an effective surface disinfectant, as reflected by ACC and ATP bioluminescence assays. ATP bioluminescence assays can be used as a tool to monitor the effectiveness of cleaning practices while using an activated hydrogen peroxide disinfectant. Additional studies are warranted to determine whether ATP and ACC cutoff points used to classify surfaces as clean should vary depending on the surface sampled.”
Friedman et al. 2013^15^ | VRE-positive samples a | VRE colonization rates, rate per 1,000 patient days | “During use of a chlorine-based, 3-staged protocol, significantly higher residual levels of VRE contamination were identified, compared with levels detected during use of a benzalkonium chloride based product for disinfection. This reduction in VRE may be due to a new disinfection product, more attention to the thoroughness of cleaning, or other supplementary efforts in our institution.”
Gillespie et al. 2013^16^ | RLU^d^ | NR | “Our pilot study supports using ultramicrofiber cloth and steam technology as an alternative to cleaning with chemicals.”
Hess et al. 2013^17^ | Contamination rates for health care worker gowns and gloves^d^ | NR | “Intense enhanced daily cleaning of ICU rooms occupied by patients colonized with MRSA or MDRAB was associated with a nonsignificant reduction in contamination of HCW gowns and gloves after routine patient care activities. Further research is needed to determine whether intense environmental cleaning will lead to significant reductions and fewer infections.”
Levin et al. 2013^18^ | Hospital-associated CDI rate per 10,000 patient days^b^ | HA-CDI attributable deaths, HA-CDI attributable colectomies | “In 2010, the HA-CDI rate was 9.46 per 10,000 patient-days; in 2011, the HA-CDI rates was 4.45 per 10,000 patient-days (53% reduction, P = .01). The number of deaths and colectomies attributable to hospital-associated C difficile infection also declined dramatically.”
Mahida et al. 2013^19^ | CFU a | Disinfection times | “UV-C is an emerging decontamination technology that is effective in reducing bacterial contamination in the clinical environment. There are significant advantages to using UV-C, and, based on the results of this study we would recommend using Tru-D at the higher reflected dose setting of 22,000 mWs/cm^2^ for terminal room disinfection in most healthcare settings.”
Manian et al. 2013^20^ | C. diff-associated diarrhea rate per 1,000 patient days^b^ | NR | “Implementation of an enhanced hospital-wide terminal cleaning program revolving around HPV decontamination of targeted hospital rooms was practical, safe, and associated with a significant reduction in the endemic rate of CDAD at our hospital. Further studies are needed to delineate better the role of HPV decontamination in reducing the endemic rate of transmission of other pathogens with significant environmental presence in hospitals.”
Passaretti et al. 2013^21^ | Adjusted incidence rate ratio^b^ | Proportion of contaminated rooms, MDRO matches/differs from the current room occupant | “HPV decontamination reduced environmental contamination and the risk of acquiring MDROs compared with standard cleaning protocols.”
Salgado et al. 2013^22^ | Rate of colonization^c^ | Length of stay, mortality | “Patients cared for in ICU rooms with copper alloy surfaces had a significantly lower rate of incident HAI and/or colonization with MRSA or VRE than did patients treated in standard rooms. Additional studies are needed to determine the clinical effect of copper alloy surfaces in additional patient populations and settings.”
Schmidt et al. 2013^23^ | Bacterial burden a | NR | “Copper, when used to surface hospital bed rails, was found to consistently limit surface bacterial burden before and after cleaning through its continuous antimicrobial activity.”
Sigler and Hensley 2013^24^ | PCR positive for staph a | NR | “Overall, genetic markers for several staphylococci known to colonize and infect humans remained ubiquitous in each room following daily disinfection practices.”
Sitzlar et al. 2013^25^ | Percent of targets cleaned a | Disinfection as measured by cultures | “An intervention that included education as well as monitoring and feedback improved thoroughness of cleaning but did not significantly improve CDI room disinfection. The use of an automated UV device improved disinfection, but 35% of rooms remained culture positive after use. Disinfection was dramatically improved through formation of a dedicated daily disinfection team and implementation of a standardized process for clearing CDI rooms.”
Goldenberg et al. 2012^26^ | Number of contaminated sites a | CDI rate | “The prevalence of environmental contamination was unaffected with a rate of 8% (9/120) before and 8% (17/212) following the change. Rates of patient infection were also unchanged during these periods.”
Grabsch et al. 2012^27^ | VRE colonization^c^ | Newly recognized VRE colonization, total burden of inpatient VRE colonization | “The Bleach-Clean programme was associated with marked reductions in new VRE colonizations in high-risk patients, and VRE bacteraemia across the entire hospital. These findings have important implications for VRE control in endemic healthcare settings.”
Havill et al. 2012^28^ | ACC^a^ | NR | “Both HPV and UVC reduce bacterial contamination, including spores, in patient rooms, but HPV is significantly more effective. UVC is significantly less effective for sites that are out of direct line of sight.”
Karpanen et al. 2012^29^* | CFU^a^ | NR | “Copper alloys (greater than or equal to 58% copper), when incorporated into various hospital furnishings and fittings, reduce the surface microorganisms. The use of copper in combination with optimal infection-prevention strategies may therefore further reduce the risk that patients will acquire infection in healthcare environments.”
Kundrapu et al. 2012^30^ | CFU^a^ | Frequency of health care worker hand contamination | “In a randomized nonblinded trial, we demonstrated that daily disinfection of high-touch surfaces in rooms of patients with Clostridium difficile infection and methicillin-resistant Staphylococcus aureus colonization reduced acquisition of the pathogens on hands after contacting high-touch surfaces and reduced contamination of hands of healthcare workers caring for the patients.”
Schmidt et al. 2012^31^ | CFU^a^ | Overall microbial burden | “There was no difference in effectiveness, with a mean relative reduction of microbial burden of 84% for the traditional method versus 88% for the PureMist method.”
Schmidt et al. 2012^32^ | CFU^a^ | NR | “The introduction of copper surfaces to objects formerly covered with plastic, wood, stainless steel, and other materials found in the patient care environment significantly reduced the overall MB on a continuous basis, thereby providing a potentially safer environment for hospital patients, health care workers (HCWs), and visitors.”
Boyce et al. 2011^33^ | Mean ACC (CFU per plate)^a^ | Proportion of surfaces yielding a positive culture result (more than 1 CFU); number of surfaces yielding >2.5 CUs/cm^2^ for the ACC | “The mobile UV-C light unit significantly reduced aerobic colony counts and C. difficile spores on contaminated surfaces in patient rooms.”
Carter and Barry 2011^34^ | CDI rate per 1,000 patients, overall rate of C. diff infection^b^ | NR | “The introduction of sporicidal wipes resulted in a significant reduction in C. difficile rates. This supports the need to review and enhance traditional environmental cleaning regimens for preventing and controlling C difficile in acute settings.”
Chan et al. 2011^35^ | CFU^a^ | NR | “These results showed that dry hydrogen peroxide vapour room decontamination is highly effective on a range of surfaces, although the cleanliness data obtained by these methods cannot be easily compared among the different surfaces as recovery of organisms is affected by the nature of the surface.”
Orenstein et al. 2011^36^ | C. diff incidence rates^b^ | NR | “We found that daily room cleaning with 0.55% germicidal bleach wipes led to a sustained reduction in hospital-acquired CDI on units with high endemic incidence of CDI. Targeting the use of daily bleach wipe cleaning to units with an increased C. difficile colonization pressure is an effective method to wipe out healthcare-acquired CDI.”
Sexton et al. 2011^37^ | CFU^a^ | Log(10) reduction | “The steam vapor system reduced bacterial levels by >90% and reduced pathogen levels on most surfaces to below the detection limit. The steam vapor system provides a means to reduce levels of microorganisms on hospital surfaces without the drawbacks associated with chemicals, and may decrease the risk of cross-contamination.”
Wilson et al. 2011^38^ | Number of bed areas from which target pathogens were isolated at least once during a sampling day^d^ | Unpooled results of screening for the target pathogens in bed/communal areas, total ACC | “Enhanced cleaning reduced environmental contamination and hand carriage, but no significant effect was observed on patient acquisition of methicillin-resistant Staphylococcus aureus.”
Alfa et al. 2010^39^ | CFU a | NR | “Our data indicate that the AHP formulation evaluated that has some sporicidal activity was significantly better than the currently used SHP formulation. This AHP formulation provides a one-step process that significantly lowers the C. difficile spore level in toilets during non-outbreak conditions without the workplace safety concerns associated with 5,000 ppm bleach.”
Casey et al. 2010^40^ | Median CFU/cm^2^ a | NR | “The results of this trial clearly demonstrate that copper-containing items offer the potential to significantly reduce the numbers of micro-organisms in the clinical environment. However, the use of antimicrobial surfaces should not act as a replacement for cleaning in clinical areas, but as an adjunct in the fight against HCAI.”
Hacek et al. 2010^41^ | C. diff cases per 1,000 patient days^b^ | NR | “The implementation of a thorough, all-surface terminal bleach cleaning program in the rooms of patients with CDI has made a sustained, significant impact on reducing the rate of nosocomial CDI in our health care system.”
Hamilton et al. 2010^42^ | Total viable bacterial counts^a^ | NR | “Cleaning with UMF reduces TVC in the hospital environment and this effect is significantly enhanced (about two-fold) with additional CuWB50. The copper-based biocide has two beneficial effects: (i) a residual effect that requires 2-3 weeks of cleaning to establish, and (ii) an immediate effect on reducing TVC that is most evident shortly after cleaning.”
Hedin et al. 2010^43^ | Total ACC a | NR | “Significantly fewer bacteria were found on Appeartex-treated surfaces compared with untreated surfaces.”
Nerandzic et al. 2010^44^ | Positive cultures a | Ease of use | “The Tru-D Rapid Room Disinfection device is a novel, automated, and efficient environmental disinfection technology that significantly reduces C. difficile, VRE and MRSA contamination on commonly touched hospital surfaces.”
Rutala et al. 2010^45^ | Total CFUs per site a | NR | “This UV-C device was effective in eliminating vegetative bacteria on contaminated surfaces both in the line of sight and behind objects within approximately 15 minutes and in eliminating C. difficile spores within 50 minutes.”
Andersen et al. 2009^46^ | CFU a | CFU in air, ease of use of ATP | “Wet, moist and dry mopping seemed to be more effective in reducing bacteria on the floor, than the spray mopping (P=0.007, p=0.002 and p=0.011, respectively). The burden of bacteria in air increased for all methods just after mopping. The overall best cleaning methods seemed to be moist and wet mopping.”
McMullen et al. 2007^47^ | Cases of C. diff-associated diarrhea per 1,000 patient days^b^ | NR | “These findings are further evidence that use of sodium hypochlorite solution may be an effective means of reducing the occurrence of CDAD in acute care facilities where the disease is epidemic or hyperendemic.”
Whitaker et al. 2007^48^ | C. diff infection rate per 1,000 patient days^b^ | NR | “A combination of automated daily isolation reports, use of a standardized methodology for isolation rounds, as well as development of a 10% hypochlorite disinfection protocol resulted in a dramatic decrease in health care-associated C difficile cases. Weekly nursing director reports and daily rounds by nursing leadership keep the direct line supervisors abreast of infection control issues on their respective nursing units. The addition of the dual-chamber bleach container ensured that the proper dilution was achieved when disinfecting reusable equipment.”
De Lorenzi et al. 2006^49^ | ACC a | NR | “Dry wiping followed by damp washing did not produce any significant reduction in the average bacterial load. However, damp washing followed by dry wiping reduced the bacterial load for both types of flooring. The difference was statistically significant.”
Wilcox et al. 2003^50^ | Incidence rate of C. diff infection^b^ | Surface colonization | “Our results provide some evidence that hypochlorite environmental cleaning may significantly reduce CDI incidence, but also emphasize the potential for confounding factors.”
Byers et al. 1998^51^ | Number of colonized sites^c^ | Cost of labor and supplies, cost of keeping room empty | “Sixteen percent of hospital room surfaces remained colonized by VRE after routine terminal disinfection. Disinfection with a new “bucket method” resulted in uniformly negative cultures. Conventional cleaning took an average of 2.8 disinfections to eradicate VRE from a hospital room, while only one cleaning was required with the bucket method.”

ACC=aerobic colony counts; AHP=accelerated hydrogen peroxide; ATP=adenosine triphosphate; CD=cleaning and disinfection; CDAD=Clostridium difficile-associated diarrhea; CDI=Clostridium difficile infection; CFU=colony-forming unit; C diff=Clostridium difficile; HA-CDI=hospital-associated Clostridium difficile infection; HAI=hospital-associated infection; HCAI=healthcare-associated infection; HCW=healthcare worker; HP=hydrogen peroxide; HPC=heterotrophic plate counts; HPD=hydrogen peroxide decontamination; HPV=hydrogen peroxide vapor; ICU=intensive care unit; MB=microbial burden; MDRAB= multidrug-resistant Acinetobacter baumannii; MDRO=multiple-drug-resistant organisms; MRSA=methicillin-resistant staphylococcus aureus; MSSA=methicillin-susceptible staphylococcus aureus; PPX-UV=pulsed xenon ultraviolet light; RLU=relative light unit; RTU=ready-to-use; SHP=stabilized hydrogen peroxide; TVC= total viable (bacterial) counts; UMF=ultramicrofiber; UVD= ultraviolet environmental disinfection; VRE=vancomycin-resistant enterococci.

a Primary outcome focused on surface contamination

b infection rate

c colonization

d other outcomes.

Table C-5 Characteristics of monitoring studies

Author | Country | Study Design | Monitoring Method | Study Length | Sample Size | Primary Setting | Pathogens | High Touch Object(s)
Luick et al. 2013^52^ | United States | Nonrandomized controlled | ATP bioluminescence, fluorescent/UV markers, visual observation | 2 months | 50 rooms, 250 total surfaces | Ward not specified | NR | Bed rail, call button, toilet, tray table, telephone
Smith et al. 2013^53^ | United States | Nonrandomized controlled | ATP bioluminescence, visual observation, swab cultures | Not reported | 10 rooms | Ward not specified | Various pathogens including C. diff, MRSA, VRE | Bed rail, call button, light switch, side table, toilet, sink, telephone, door handle
Snyder et al. 2013^54^ | United States | Nonrandomized controlled | ATP bioluminescence, fluorescent/UV markers, visual observation | 3 months | 20 rooms, 290 surfaces | Ward not specified | NR | Bed rail, call button, light switch, side table, toilet, tray table, door knob, telephone, sink
Mulvey et al. 2011^55^ | United Kingdom | Nonrandomized controlled | ATP bioluminescence, visual observation, Agar slide cultures | 4 weeks | 90 samples | General medical and surgical wards | MRSA | Bed, bed rail, floor, tray table
Munoz-Price et al. 2011^56^ | United States | ITS | Fluorescent/UV markers | 20 weeks | 284 rooms, 2,292 surfaces | ICU | Various pathogens | Bed rail, bed control, call button, light switch, monitor control panel, remote control, side table, toilet, tray table
Carling et al. 2010^57^ | United States | Before/after | Fluorescent/UV markers | Not reported | 260 rooms, 3,532 samples, 27 hospitals | ICU | NR | NR
Alfa et al. 2008^58^ | Not specified | Descriptive | Fluorescent/UV markers | 8 months | 20 patients, 201 samples | Ward not specified | C. diff | Toilet
Alhamad and Maxwell 2008^59^ | United Kingdom | Before/after and correlation of 2 monitoring methods | Agar slide cultures, “wipe-rinse method,” used an assay | 4 weeks | 130 samples | Intensive care unit and “high dependency unit” | MRSA | Bed rail, monitor control panel, cabinet, door handle, telephone, keyboard
Blue et al. 2008^60^ | Canada | Before/after | Fluorescent/UV markers | 4 months | 364 samples | Ward not specified | VRE | Bed rail, call buttons light switch, toilet, tray table, doorknob
Carling et al. 2008^61^ | United States | Descriptive study of UV fluorescent monitoring | Fluorescent/UV markers | 12 weeks | 1,119 rooms, 13,369 “high risk-objects” | ICU and other units | NR | Bed rail, call button, light switch, side table, toilet, tray table, sink, telephone, doorknob
Carling et al. 2006^62^ | United States | Descriptive study of fluorescent marker monitoring | Fluorescent/UV markers | Not reported | 157 rooms, 1,404 samples | Ward not specified | NR | Bed rail, call button, side table, toilet, tray table, sink, doorknob, telephone
Malik et al. 2003^63^ | United Kingdom | Nonrandomized controlled | ATP bioluminescence, visual observation, Agar slide cultures | Not reported | 8 hospital wards | Ward not specified | NR | Not specified

ATP=adenosine triphosphate; C-diff=Clostridium difficile; HTO=high touch object; ICU=intensive care unit; ITS=interrupted time series; MRSA=methicillin-resistant staphylococcus aureus; NR=not reported; UV=ultraviolet; VRE=vancomycin-resistant enterococci.

Table C-6 Methods for monitoring studies*

Author | Monitoring Methods | Implementation Tools | Discusses Sustainability
Luick et al. 2013^52^ | ATP bioluminescence, fluorescent/UV markers, visual observation | Not reported | No
Smith et al. 2013^53^ | ATP bioluminescence, visual observation, swab cultures | Not reported | No
Snyder et al. 2013^54^ | ATP bioluminescence, fluorescent/UV markers, visual observation | Not reported | No
Mulvey et al. 2011^55^ | ATP bioluminescence, visual observation, Agar slide cultures | Not reported | No
Munoz-Price et al. 2011^56^ | Fluorescent/UV markers | Feedback of UV-powder surveillance to environmental services, hospital leadership, and unit administrators. | Yes
Carling et al. 2010^57^ | Fluorescent/UV markers | Feedback and education to staff | No
Alfa et al. 2008^58^ | Fluorescent/UV markers | Not reported | No
Alhamad and Maxwell 2008^59^ | Agar slide cultures, “wipe-rinse method,” uses an assay | Not reported | No
Blue et al. 2008^60^ | Fluorescent/UV markers | Includes regular feedback to EVS personnel | No
Carling et al. 2008^61^ | Fluorescent/UV markers | Not reported | No
Carling et al. 2006^62^ | Fluorescent/UV markers | Not reported | No
Malik et al. 2003^63^ | ATP bioluminescence, visual observation, Agar slide cultures | Not reported | No

Cleaning methods, external factors, and patient safety culture were not reported.

ATP=adenosine triphosphate; CDI=Clostridium difficile infection; EVS=environmental services.

Table C-7 Outcomes and conclusions for monitoring studies

Author | Primary Outcome | Secondary Outcome of Interest | Authors' Conclusions
Luick et al. 2013^52^ | Sensitivity to detect pathogens | Specificity of tests, PPV, NPV | “In a simultaneous assessment of 250 environmental surfaces after terminal cleaning using aerobic cultures as a gold standard, both fluorescent marker and an adenosine triphosphate bioluminescence assay system demonstrated better diagnosticity compared with subjective visual inspection.”
Smith et al. 2013^53^ | RLU/cm^2^; CFU/cm^2^ | NR | “Although quantitative microbiology and ATP detection measure somewhat different aspects of environmental contamination, they both generally agree in distinguishing clean from dirty surfaces.”
Snyder et al. 2013^54^ | Percent of targets cleaned | Test characteristics of UV, ATP, and visual inspection | “In assessing the effectiveness of PDC, there was poor correlation between the two most frequently studied commercial methods and a microbiologic comparator. Visual inspection performed at least as well as commercial methods, directly addresses patient perception of cleanliness, and is economical to implement.”
Mulvey et al. 2011^55^ | Cleaning rate | Surface contamination (measured by ATP and dipslides) | “Microbiological and ATP monitoring confirmed environmental contamination, persistence of hospital pathogens and measured the effect on the environment from current cleaning practices. This study has provided provisional benchmarks to assist with future assessment of hospital cleanliness. Further work is required to refine practical sampling strategy and choice of benchmarks.”
Munoz-Price et al. 2011^56^ | Cleaning rate | NR | “We found that regular surveillance using an inexpensive technology coupled with regular feedback of results produced sustained improvements in environmental cleaning, which may explain the coincident reduction in hospital-acquired infections. The ability of this brief (12 weeks) intervention to produce rapid benefits (within 4 weeks) and prolonged benefits (more than 20 weeks) speaks to its efficacy. Further studies aimed at optimizing reintroduction of the intervention to optimize cleaning rates should be considered.”
Carling et al. 2010^57^ | Percent of targets cleaned | NR | “Significant improvements in intensive care unit room cleaning can be achieved in most hospitals by using a structured approach that incorporates a simple, highly objective surface targeting method and repeated performance feedback to environmental services personnel.”
Alfa et al. 2008^58^ | Cleaning rate | NR | “Our data demonstrated the value of UVM for monitoring the compliance of housekeeping staff with the facility's toilet cleaning protocol. In addition to providing good physical cleaning action, agents with some sporicidal activity against C. difficile may be needed to effectively reduce the environmental reservoir.”
Alhamad and Maxwell 2008^59^ | Number of samples with positive culture | Overall CFU/cm^2^ | “There was no direct correlation between the findings of total aerobic count and MRSA isolation. We suggest, however, that combining both standards will give a more effective method of assessing the efficacy of cleaning/disinfection strategy. Further work is required to evaluate and refine these standards in order to assess the frequency of cleaning required for a particular area, or for changing the protocol or materials used.”
Blue et al. 2008^60^ | Percent of targets cleaned | VRE infection rate | “The GlitterBug product is an effective tool to evaluate environmental cleaning and adherence to policies and procedures and this method was superior to previous visual inspection methods. The use of GlitterBug potion improved physical cleaning and enhanced staff contribution. The Brevis GlitterBug product was incorporated into the CSS environmental cleaning program at Hamilton Health Sciences as a quality indicator to monitor environmental cleaning practices.”
Carling et al. 2008^61^ | Cleaning rate | NR | “We identified significant opportunities in all participating hospitals to improve the cleaning of frequently touched objects in the patient's immediate environment. The information obtained from such assessments can be used to develop focused administrative and educational interventions that incorporate ongoing feedback to the environmental services staff, to improve cleaning and disinfection practices in healthcare institutions.”
Carling et al. 2006^62^ | Percent of targets cleaned | NR | “The use of a novel target compound to evaluate housekeeping practices confirmed high rates of cleaning of traditional sites but poor cleaning of many sites that have significant potential for harboring and transmitting microbial pathogens. This methodology has the potential for being used to evaluate objectively the cleaning/disinfecting activities in various health care settings.”
Malik et al. 2003^63^ | RLU, CFU/cm^2^ | NR | “The data suggest that visual assessment is a poor indicator of cleaning efficacy and that the ACE audit gives a better assessment of cleaning programs compared with the other 2 audit methods in relation to microbial surface counts. It is recommended that hospital cleaning regimes be designed to ensure that surfaces are cleaned adequately and that efficacy is assessed with use of internal auditing and rapid hygiene testing.”

ACC=aerobic colony count; ACE=audit for cleaning efficacy; ATP=adenosine triphosphate; CDI=Clostridium difficile infection; CFU=colony-forming unit; CSS=infection control and customer support services; MRSA=methicillin-resistant staphylococcus aureus; NPV=negative predictive value; NR=not reported; PDC=postdischarge cleaning; PPV=positive predictive value; RLU=relative light unit; UVM=ultraviolet visible marker.

Table C-8 Characteristics of implementation studies

Author | Country | Study Design | Study Length | Single or Multicomponent Strategy | Sample Size | Primary Setting | Pathogen(s) Described | High Touch Object(s)
Branch-Elliman et al. 2014^64^ | United States | Before/after | 2 months | Single | 820 surfaces, 210 rooms | Ward not specified | MRSA, VRE | Side rail, over-bed rail, toilet seat
Koll et al. 2014^65^ | United States | ITS | 22 months | Multicomponent/infection prevention bundle, including contact precautions for patients with diarrhea and sign placement for patients with confirmed/suspected CDI | 35 hospitals | Burn, telemetry and medical surgical unit | C. diff | Over 20 HTOs, including bed, bed rail, call button, floor, toilet, tray table, over 20 HTOs
Ramphal et al. 2014^66^ | United States | ITS | 14 months | Multicomponent/hand hygiene, improved kits for line-changing procedures | 3,185 HTOs | Ward not specified | Various pathogens, including C. diff | 20 HTOs, including bed rail, call button, remote control, and tray table
Rupp et al. 2014^67^ | United States | Before/after | 4 years | Single | 90 rooms, 1,117 surface measurements | Medical/surgical critical care units | NR | Bed rail, tray table, room door handle, thermometer, monitor, bed rail, release button, nurse call monitor, and other items
Rupp et al. 2014^68^ | United States | Observation­al | 4 months | Single | 292 rooms, 17 housekeepers | Surgical/medical ICU | NR | 18 HTOs, including bed rail, call button, light switch, and toilet
Smith et al. 2014^69^ | United States | Non-RCT | 20 months | Single | 13,345 sites | 5 units, including telemetry, ICU, medical/surgical, and cardiac | C. diff, MRSA, VRE | 16 HTOs, including toilet seat, light switch, call light, mattress, and bedrail
Brakovich et al. 2013^70^ | United States | ITS | 7 months | Multicomponent/a tiered approach that included environmental cleaning and disinfection, diagnostics and surveillance, and infection control measures, including antibiotic stewardship | 50 beds | Long-term acute care hospital | C. diff | Not specified
Trajtman et al. 2013^71^ | Canada | Non-RCT | 24 weeks | Single | 7,680 sites | General medical ward | C. diff | Bathroom
Ragan et al. 2012^72^ | Canada | Before/after | 8 weeks | Single | 823 HTO | ICU | C. diff, MRSA, VRE | Light switch, toilet, tray table, IV pole, drawer handle, door knob and other items
Datta et al. 2011^73^ | United States | Retro­spective cohort | 19 months | Single | 17,652 patients | ICU | MRSA, VRE | Not specified
Murphy et al. 2011^74^ | Australia | Before/after | 17 weeks | Single | 37 rooms, 986 HTOs | Ward not specified | MRSA, VRE | Light switch, toilet, bedroom door handle, bedroom soap dispenser, bedroom tap handle, paper towel dispenser
Hota et al. 2009^75^ | United States | Before/after | 25 weeks | Single | 2,901 sites for thoroughness of cleaning, 1,472 sites for contamination | ICU | VRE | Bed rail, tray table, infusion pump; countertop; soap dispenser, and other items
Po et al. 2009^76^ | United States | ITS | 9 months | Single | 16 bed | ICU | C. diff, VRE | Computer keyboard on wheels
Carling et al. 2008^77^ | United States | Before/after | NR | Single | 20,646 HTOs | General medical ward, special care areas | C. diff, MRSA, VRE | 14 HTOs including bed rail, toilet, and tray table
Goodman et al. 2008^78^ | United States | Before/after | 8 months | Single | 85 rooms, 1,121 surfaces | Respiratory step-down unit | MRSA, VRE | 15 HTOs, including bed rail, curtain, light switch, and toilet
Eckstein et al. 2007^79^ | United States | Before/after | 16 weeks | Single | 17 rooms | Surgical ward | C. diff, VRE | Bed rail, call button, side table, toilet, and door knob
Hayden et al. 2006^80^ | United States | Before/after | 255 days | NR | 485 cleaning episodes | ICU | VRE | Bed rail, infusion pump, countertop, door handle, telephone, and other items

CDI=Clostridium difficile infection; C. diff=Clostridium difficile; HTO=high touch object; ICU=intensive care unit; ITS=interrupted time series; IV=intravenous; MRSA=methicillin-resistant staphylococcus aureus; non-RCT=nonrandomized controlled trial; NR=not reported; VRE=vancomycin-resistant enterococci.

Table C-9 Methods for implementation studies

Author | Cleaning Methods | Monitoring Methods | External Factors | Patient Safety Culture | Implementation Tools | Discusses Sustainability
Branch-Elliman et al. 2014^64^ | NR | ATP bioluminescence | NR | NR | Education, monitoring, feedback | Yes
Koll et al. 2014^65^ | Hypochlorite-based disinfectant | NR | NR | NR | Cleaning checklists | NR
Ramphal et al. 2014^66^ | NR | Fluorescent/UV markers | NR | NR | Education, training, “blinded monitoring with transparent reporting of the results in a positive, engaging manner” | Yes
Rupp et al. 2014^67^ | NR | Fluorescent/UV markers | NR | Department of infection control | 43-point room-cleaning checklist, housekeeper educational program, training DVD, face-to-face meetings with housekeeping | Yes
Rupp et al. 2014^68^ | Routine | ATP bioluminescence | NR | NR | NR | NR
Smith et al. 2014^69^ | Quaternary ammonium | ATP bioluminescence | NR | NR | Educational interventional activities such as hands-on training and education with ATP devices, education via “Clean Sweep” electronic game, laminated pocket-size cleaning order, and high-touch surface lists in both English and Spanish. | Yes
Brakovich et al. 2013^70^ | Microfiber mops, HPV | NR | Outside contractor provided HPV devices and services for followup decontamination of rooms formerly occupied by patients with CDI | IP Registered Nurse, members of the Quality and Safety Committee, Clinical Quality Outcomes Coordinator | Lipstick challenge, checklists, training on use of chemicals, color-coded microfiber cloths, database output of quarterly reports | Yes
Trajtman et al. 2013^71^ | NR | Fluorescent/UV markers | NR | NR | Feedback and UVM audit tool | Yes
Ragan et al. 2012^72^ | NR | Fluorescent/UV markers | NR | NR | Audit and feedback, check list for HTOs | NR
Datta et al. 2011^73^ | Quaternary ammonium, change in application of disinfectant to bucket immersion of cloths | Fluorescent/UV markers | NR | NR | Education | NR
Murphy et al. 2011^74^ | NR | Fluorescent/UV markers | NR | EVS management from 2 participating hospitals were given advice to better understand and improve cleaning | Audit and feedback, education to EVS staff, survey of EVS staff | Yes
Hota et al. 2009^75^ | Quaternary ammonium | Swab cultures | NR | NR | Education, intensified monitoring | NR
Po et al. 2009^76^ | NR | Fluorescent/UV markers | NR | NR | Education and feedback, process improvement interventions (e.g., assigned 1 specific individual to clean COWS), modification to cleaning protocols | Yes
Carling et al. 2008^77^ | NR | Fluorescent/UV markers | NR | Hospital directors at all participating hospitals reviewed evaluation of terminal room cleaning practices with EVS management and subsequently presented this information to frontline staff; active interhospital networking | Audit and feedback | Yes
Goodman et al. 2008^78^ | Quaternary ammonium (change from pour bottles to immersing cloth in bucket) | ATP bioluminescence, swab cultures | NR | NR | Education, monitoring, and feedback | NR
Eckstein et al. 2007^79^ | NR | Swab cultures | NR | Infection Control Department meets monthly with housekeeping to provide feedback on culture results and to reconfirm importance of housekeeping in controlling pathogens | Audit and feedback, education, housekeeping staff asked for input on additional resources needed to perform job well | NR
Hayden et al. 2006^80^ | Quaternary ammonium | Visual observation, VRE cultures | NR | NR | Educational in services, increased monitoring, audit, and feedback | NR

ATP=adenosine triphosphate; CDI=Clostridium difficile infection; COW=computer on wheels; EVS=environmental services; HPV=hydrogen peroxide vapor; HTO=high touch objects; IP=Infection prevention; NR=not reported; UVM=ultraviolet visible marker; VRE=vancomycin-resistant enterococci.

Table C-10 Outcomes and conclusions for implementation studies

Author | Primary Outcome | Secondary Outcome of Interest | Authors' Conclusions
Branch-Elliman et al. 2014^64^ | Proportion of surfaces cleaned | NR | “We successfully implemented a quality improvement and education project to improve environmental cleaning in our hospital. Our study demonstrates that quality-assessment tools, such as the ATP luminometer, can be used at the point of cleaning to improve cleaning performance. Use of the tool in a positive feedback loop directly with front-line EMS staff resulted in enhanced collaboration, communication, and education among services.”
Koll et al. 2014^65^ | Compliance with room cleaning protocol | CDI rates | “The use of a collaborative model to implement a multifaceted infection prevention strategy was temporally associated with a significant reduction in hospital-onset CDI rates in participating New York metropolitan regional hospitals.”
Ramphal et al. 2014^66^ | Percent of targets cleaned | C. diff rate per 1,000 patient days | “The percentage of cleaned surfaces improved incrementally between the three trials—with values of 20%, 49%, and 82%—showing that repeat training favorably changed behavior in the staff (P = 0.007). During the study period, during which other infection control interventions were also introduced, there was a decline from 0.27 to 0.21 per 1000 patient days for Clostridium difficile infection, 0.43 to 0.21 per 1000 patient days for ventilator-associated infections, 1.8% to 1.2% for surgical site infections, and 1.2 to 0.7 per 1000 central venous line days for central line–associated bloodstream infections.”
Rupp et al. 2014^67^ | Compliance with room cleaning protocol | NR | “Over a 4-year period, we observed that monthly feedback of performance data in face-to-face meetings with frontline personnel was crucial in maintaining environmental-cleaning effectiveness in adult critical care units.”
Rupp et al. 2014^68^ | Housekeeper efficiency and effectiveness based on RLUs | NR | “A subgroup of housekeepers was identified who were significantly more effective and efficient than their coworkers. These optimum outliers may be used in performance improvement to optimize environmental cleaning.”
Smith et al. 2014^69^ | Cleaning score measures over time | Trends in HAIs | “The ATP detection device combined with educational feedback for EVS workers resulted in significant improvement in cleaning efficacy of the hospital room environment.”
Brakovich et al. 2013^70^ | Incidence rate of CDI | Cost | “This program was successful in decreasing the incidence of CDI in the LTACH creating a safe and cost-effective environment for patients, families, and the community.”
Trajtman et al. 2013^71^ | Compliance with room cleaning protocol | NR | “The use of UVM as an audit tool combined with weekly feedback of results to housekeeping staff resulted in significant, sustained improvement in the overall level of cleaning compliance of housekeeping staff.”
Ragan et al. 2012^72^ | Percent of targets cleaned | NR | “We demonstrate that auditing with fluorescent targeting can be implemented in both the ward and intensive care unit settings using only modest resources, resulting in rapid improvements in cleaning thoroughness.”
Datta et al. 2011^73^ | Infection rate: MRSA and VRE | Acquisition by prior occupant status | “Enhanced intensive care unit cleaning using the intervention methods may reduce MRSA and VRE transmission. It may also eliminate the risk of MRSA acquisition due to an MRSA-positive prior room occupant.”
Murphy et al. 2011^74^ | Compliance with room cleaning protocol | Percent of targets cleaned | “The [fluorescent marker] was useful to assess HTO cleaning thoroughness. It facilitated relevant feedback and education and motivated staff to strive for continual improvements in environmental cleaning. Without on-going education, preliminary improvements were unsustained. However, investigators better understood flaws in cleaning and policy/procedure conflicts.”
Hota et al. 2009^75^ | Percent of targets cleaned | Contamination of sites postcleaning, VRE prevalence | “These findings suggest that surface contamination with VRE is due to a failure to clean rather than to a faulty cleaning procedure or product.”
Po et al. 2009^76^ | Cleaning rate | NR | “Following a series of educational and programmatic interventions, we were able to improve the thoroughness of cleaning to 100%.”
Carling et al. 2008^77^ | Percent of targets cleaned | NR | “Significant improvements in disinfection cleaning can be achieved in most hospitals, without a substantial added fiscal commitment, by the use of a structured approach that incorporates a simple, highly objective surface targeting method, repeated performance feedback to environmental services personnel, and administrative interventions. However, administrative leadership and institutional flexibility are necessary to achieve success, and sustainability requires an ongoing programmatic commitment from each institution.”
Goodman et al. 2008^78^ | Positive cultures | Number of rooms with positive culture | “Increasing the volume of disinfectant applied to environmental surfaces, providing education for Environmental Services staff, and instituting feedback with a black-light marker improved cleaning and reduced the frequency of MRSA and VRE contamination.”
Eckstein et al. 2007^79^ | Percent of positive cultures | NR | “Our findings provide additional evidence that simple educational interventions directed at housekeeping staff can result in improved decontamination of environmental surfaces. Such interventions should include efforts to monitor cleaning and disinfection practices and provide feedback to the housekeeping staff.”
Hayden et al. 2006^80^ | Colonization with VRE | Time to clean, antibiotic use | “Decreasing environmental contamination may help to control the spread of some antibiotic resistant bacteria in hospitals.”

ATP=adenosine triphosphate; CDI=Clostridium difficile infection; EVS=environmental services; HAI=hospital-associated infection; HTO=high touch object; LTACH=long-term acute care hospital; MRSA=methicillin-resistant staphylococcus aureus; RLU=relative light unit; UVM=ultraviolet visible marker; VRE=vancomycin-resistant enterococci.