# Excluded Studies Based on Review of Full-Length Articles

## Not a location or setting of interest

Aiken ZA, Wilson M, Pratten J. Evaluation of ATP bioluminescence assays for potential use in a hospital setting. Infect Control Hosp Epidemiol. May. 2011;32(5):507-9. [pmid: 21515983].
Alfa MJ, Lo E, Olson N, et al. Use of a daily disinfectant cleaner instead of a daily cleaner reduced hospital-acquired infection rates. Am J Infect Control. Feb. 1. 2015;43(2):141-6. http://dx.doi.org/10.1016/j.ajic.2014.10.016. [pmid: 25534117].
Ali S, Moore G, Wilson AP. Effect of surface coating and finish upon the cleanability of bed rails and the spread of Staphylococcus aureus. J Hosp Infect. Mar. 2012;80(3):192-8. [pmid: 22264495].
Allen G. Implementing AORN recommended practices for environmental cleaning. AORN J. May. 2014;99(5):570-82. [pmid: 24766919].
Bartels MD, Kristoffersen K, Slotsbjerg T, et al. Environmental meticillin-resistant Staphylococcus aureus (MRSA) disinfection using dry-mist-generated hydrogen peroxide. J Hosp Infect. Sep. 2008;70(1):35-41. [pmid: 18621434].
Berendt AE, Turnbull L, Spady D, et al. Three swipes and you're out: How many swipes are needed to decontaminate plastic with disposable wipes?. Am J Infect Control. Jun. 2011;39(5):442-3. [pmid: 21306797].
Berrington AW, Pedler SJ. Investigation of gaseous ozone for MRSA decontamination of hospital side-rooms. J Hosp Infect. Sep. 1998;40(1):61-5. [pmid: 9777523].
Bradley CR, Fraise AP. Heat and chemical resistance of enterococci. J Hosp Infect. Nov. 1996;34(3):191-6. [pmid: 8923273].
Cheng KL, Boost MV, Chung JW. Study on the effectiveness of disinfection with wipes against methicillin-resistant Staphylococcus aureus and implications for hospital hygiene. Am J Infect Control. Sep. 2011;39(7):577-80. [pmid: 21641084].
Doan L, Forrest H, Fakis A, et al. Clinical and cost effectiveness of eight disinfection methods for terminal disinfection of hospital isolation rooms contaminated with Clostridium difficile 027. J Hosp Infect. Oct. 2012;82(2):114-21. [pmid: 22902081].
Gillespie EE, Scott C, Wilson J, et al. Pilot study to measure cleaning effectiveness in health care. Am J Infect Control. Jun. 2012;40(5):477-8. [pmid: 21937146].
Gilmour D, Cooper R. Feedback from members on decontamination services. J Perioper Pract. Jul. 2008;18(7):279-80. [pmid: 18710125].
Griffith CJ, Cooper RA, Gilmore J, et al. An evaluation of hospital cleaning regimes and standards. J Hosp Infect. May. 2000;45(1):19-28. [pmid: 10833340].
Griffith CJ, Malik R, Cooper RA, et al. Environmental surface cleanliness and the potential for contamination during handwashing. Am J Infect Control. Apr. 2003;31(2):93-6. [pmid: 12665742].
Hendry E, Conway B, Worthington T. Antimicrobial efficacy of a novel eucalyptus oil, chlorhexidine digluconate and isopropyl alcohol biocide formulation. Int J Mol Sci. 2012;13(11):14016-25. [pmid: 23203047].
Hick JL, Penn P, Hanfling D, et al. Establishing and training health care facility decontamination teams. Ann Emerg Med. Sep. 1. 2003;42(3):381-90. [pmid: 12944891].
Hiom S, Lowe C, Oldcorne M. Development and validation of a method to assess alcohol transfer disinfection procedures. Pharm J. May. 15. 2004;272(7299):611-4.
Ismail S, Perni S, Pratten J, et al. Efficacy of a novel light-activated antimicrobial coating for disinfecting hospital surfaces. Infect Control Hosp Epidemiol. Nov. 2011;32(11):1130-2. [pmid: 22011544].
Jury LA, Cadnum JL, Jennings-Sanders A, et al. Evaluation of an alcohol-based power sanitizing system for decontamination of hospital rooms of patients with methicillin-resistant Staphylococcus aureus carriage. Am J Infect Control. Apr. 2010;38(3):234-6. [pmid: 20085852].
Kampf G, Bloss R, Martiny H. Surface fixation of dried blood by glutaraldehyde and peracetic acid. J Hosp Infect. Jun. 2004;57(2):139-43. [pmid: 15183244].
Kaupp S, Heizmann WR. Efficacy of disinfectants against multiresistant staphylococci. Klin Labor. 1995;41(12):979-85.
Kawakami H, Hayashi T, Nishikubo H, et al. Effects of surface contamination and cleaning with hypochlorite wipes on the antibacterial activity of copper-alloyed antibacterial stainless steel. Biocontrol Sci. 2014;19(2):73-8. [pmid: 24975410].
Lerones C, Mariscal A, Carnero M, et al. Assessing the residual antibacterial activity of clinical materials disinfected with glutaraldehyde, o-phthalaldehyde, hydrogen peroxide or 2-bromo-2-nitro-1,3-propanediol by means of a bacterial toxicity assay. Clin Microbiol Infect. Nov. 2004;10(11):984-9. [pmid: 15522001].
Lopez GU, Kitajima M, Havas A, et al. Evaluation of a disinfectant wipe intervention on fomite-to-finger microbial transfer. Appl Environ Microbiol. May. 2014;80(10):3113-8. [pmid: 24610856].
Lowe JJ, Gibbs SG, Iwen PC, et al. Impact of chlorine dioxide gas sterilization on nosocomial organism viability in a hospital room. Int J Environ Res Public Health. Jun. 2013;10(6):2596-605. [pmid: 23792697].
Matlow AG, Wray R, Richardson SE. Attitudes and beliefs, not just knowledge, influence the effectiveness of environmental cleaning by environmental service workers. Am J Infect Control. Apr. 2012;40(3):260-2. [pmid: 21741727].
Moat J, Cargill J, Shone J, et al. Application of a novel decontamination process using gaseous ozone. Can J Microbiol. Aug. 2009;55(8):928-33. [pmid: 19898532].
Nerandzic MM, Cadnum JL, Eckart KE, et al. Evaluation of a hand-held far-ultraviolet radiation device for decontamination of Clostridium difficile and other healthcare-associated pathogens. BMC Infect Dis. May. 16. 2012;12:120. [pmid: 22591268].
Oie S, Yanagi C, Matsui H, et al. Contamination of environmental surfaces by Staphylococcus aureus in a dermatological ward and its preventive measures. Biol Pharm Bull. Jan. 2005;28(1):120-3. [pmid: 15635175].
Omidbakhsh N, Ahmadpour F, Kenny N. How reliable are ATP bioluminescence meters in assessing decontamination of environmental surfaces in healthcare settings?. PLoS ONE. Jun. 18. 2014;9(6):e99951. [pmid: 24940751].
O'Neill C, Ramage L, Wyatt L, et al. Quality control is indispensable for automated dilution systems with accelerated hydrogen peroxide. Can J Infect Control. Winter. 2009;24(4):226-8. [pmid: 20128258].
Payne DN, Gibson SA, Lewis R. Antiseptics: A forgotten weapon in the control of antibiotic resistant bacteria in hospital and community settings?. J R Soc Health. 1998;118(1):18-22. [pmid: 9724934].
Perugini MR, Nomi SM, Lopes GK, et al. Impact of the reduction of environmental and equipment contamination on vancomycin-resistant enterococcus rates. Infection. Dec. 2011;39(6):587-93. [pmid: 21847554].
Pulliam JR. Lower infection rates after introduction of a photocatalytic surface coating. Am J Infect Control. Feb. 1. 2015;43(2):180-1. http://dx.doi.org/10.1016/j.ajic.2014.10.023. [pmid: 25530557].
Rutala WA, Gergen MF, Tande BM, et al. Rapid hospital room decontamination using ultraviolet (UV) light with a nanostructured UV-reflective wall coating. Infect Control Hosp Epidemiol. May. 2013;34(5):527-9. [pmid: 23571373].
Stibich M, Stachowiak J, Tanner B, et al. Evaluation of a pulsed-xenon ultraviolet room disinfection device for impact on hospital operations and microbial reduction. Infect Control Hosp Epidemiol. Mar. 2011;32(3):286-8. [pmid: 21460515].
Tekin A, Dal T, Selcuk CT, et al. Orthophenylphenol in healthcare environments: A trial related to a new administration method and a review of the literature. Turk J Med Sci. 2013;43(5):805-9.
Tyski S, Grzybowska W, Grzeszczuk S, et al. Antimicrobial activity of glucoprotamin-containing disinfectants. Polish Journal of Microbiology. 2009;58(4):347-53. [pmid: 20380145].
Umezawa K, Asai S, Inokuchi S, et al. A comparative study of the bactericidal activity and daily disinfection housekeeping surfaces by a new portable pulsed UV radiation device. Curr Microbiol. Jun. 2012;64(6):581-7. [pmid: 22447288].
Vandini A, Temmerman R, Frabetti A, et al. Hard surface biocontrol in hospitals using microbial-based cleaning products. PLoS ONE. 2014;9(9):e108598. http://dx.doi.org/10.1371/journal.pone.0108598. [pmid: 25259528].
Willis C, Morley R, Westbury J, et al. Evaluation of ATP bioluminescence swabbing as a monitoring and training tool for effective hospital cleaning. Br J Infect Control. Oct. 1. 2007;8(5):17-22.
Wren MW, Rollins MS, Jeanes A, et al. Removing bacteria from hospital surfaces: a laboratory comparison of ultramicrofibre and standard cloths. J Hosp Infect. Nov. 2008;70(3):265-71. [pmid: 18801594].
Yamazhan T, Isikgoz Tasbakan M, Calik S, et al. Evaluation of the knowledge of hospital cleaning staff about prevention of nosocomial infections. Turk J Med Sci. Feb. 2009;39(1):77-80.
You E, Song H, Cho J, et al. Reduction in the incidence of hospital-acquired Clostridium difficile infection through infection control interventions other than the restriction of antimicrobial use. Int J Infect Dis. May. 2014:e9-e10. [pmid: 24583565].

## Not a publication type of interest

Aziz A. Can education and training for domestic staff increase awareness of infection control practices and improve cleanliness within hospitals?. Journal of Infection Prevention. Sep. 1. 2009;10(5):171-8.
Borg MA. Lowbury Lecture 2013. Cultural determinants of infection control behaviour: understanding drivers and implementing effective change. J Hosp Infect. Mar. 2014;86(3):161-8. [pmid: 24534705].
Bucior H, Cochrane J. Lifting the lid: a clinical audit on commode cleaning. Journal of Infection Prevention. May. 1. 2010;11(3):73-81. http://dx.doi.org/10.1177/1757177410365945.
Coates D. How to produce a hospital disinfection policy. J Hosp Infect. 1994;26(1):57-68. [pmid: 7910184].
Dancer SJ. How do we assess hospital cleaning? A proposal for microbiological standards for surface hygiene in hospitals. J Hosp Infect. Jan. 2004;56(1):10-5. [pmid: 14706265].
Donskey CJ. Does improving surface cleaning and disinfection reduce health care-associated infections?. Am J Infect Control. May. 2013;41(5 Suppl):S12-9. [pmid: 23465603].
Galvin S, Dolan A, Cahill O, et al. Microbial monitoring of the hospital environment: why and how?. J Hosp Infect. Nov. 2012;82(3):143-51. [pmid: 23022372].
Hay A. Audit in infection control. J Hosp Infect. Mar. 2006;62(3):270-7. [pmid: 16337308].
Kossow A, Schaber S, Kipp F. Surface disinfection in the context of infection prevention in intensive care units. Med Klin Intensivmed Notfmed. 2013;108(2):113-8. [pmid: 23423577].
Maclean M, McKenzie K, Anderson JG, et al. 405 nm light technology for the inactivation of pathogens and its potential role for environmental disinfection and infection control. J Hosp Infect. Sep. 2014;88(1):1-11. [pmid: 25066049].
O'Gorman J, Humphreys H. Application of copper to prevent and control infection. Where are we now?. J Hosp Infect. Aug. 2012;81(4):217-23. [pmid: 22738611].
Otter JA, Yezli S, Perl TM, et al. The role of ‘no-touch’ automated room disinfection systems in infection prevention and control. J Hosp Infect. Jan. 2013;83(1):1-13. [pmid: 23195691].
Pearman JW. 2004 Lowbury Lecture: the Western Australian experience with vancomycin-resistant enterococci - from disaster to ongoing control. J Hosp Infect. May. 2006;63(1):14-26. [pmid: 16563562].
Piluso LG, Moffatt-Smith C. Disinfection using ultraviolet radiation as an antimicrobial agent: A review and synthesis of mechanisms and concerns. PDA J Pharm Sci Technol. Jan-Feb. 2006;60(1):1-16. [pmid: 17089676].
Rutala WA. Disinfection and sterilization of patient-care items. Infect Control Hosp Epidemiol. Jun. 1996;17(6):377-84. [pmid: 8805073].
Sattar SA, Maillard JY. The crucial role of wiping in decontamination of high-touch environmental surfaces: Review of current status and directions for the future. Am J Infect Control. May. 2013;41(5 Suppl):S97-104. [pmid: 23622759].
Siani H, Maillard JY. Best practice in healthcare environment decontamination. Eur J Clin Microbiol Infect Dis. Jan. 2015;34(1):1-11. Epub 2014 Jul 26. [pmid: 25060802].
Spruce L, Wood A. Back to basics: environmental cleaning. AORN J. Jul. 2014;100(1):54-61. quiz 62-4. [pmid: 24973185].
Varney J. Exploring and reducing healthcare associated infections on a respiratory ward. Foundation of Nursing Studies: Developing Practice Improving Care Dissemination Series. Jan. 1. 2009;5(1):1-5.
Washer LL, Chenoweth CE. Infection control strategies for methicillin-resistant staphylococcus aureus and vancomycin-resistant enterococcus: What is the evidence?. J Clin Outcome Manag. Jun. 2006;13(6):333-41.
Weber DJ, Anderson D, Rutala WA. The role of the surface environment in healthcare-associated infections. Curr Opin Infect Dis. Aug. 2013;26(4):338-44. [pmid: 23743816].

## Duplicate study population

Alfa MJ, Lo E, Olson N, et al. Use of a daily disinfectant cleaner instead of a daily cleaner reduced hospital-acquired infection rates. Am J Infect Control. Feb. 1. 2015;43(2):141-6. http://dx.doi.org/10.1016/j.ajic.2014.10.016. [pmid: 25534117].
Boyce JM, Havill NL, Dumigan DG, et al. Monitoring the effectiveness of hospital cleaning practices by use of an adenosine triphosphate bioluminescence assay. Infect Control Hosp Epidemiol. Jul. 2009;30(7):678-84. [pmid: 19489715].
Boyce JM, Havill NL, Havill HL, et al. Comparison of fluorescent marker systems with 2 quantitative methods of assessing terminal cleaning practices. Infect Control Hosp Epidemiol. Dec. 2011;32(12):1187-93. [pmid: 22080657].
Boyce JM, Havill NL, Lipka A, et al. Variations in hospital daily cleaning practices. Infect Control Hosp Epidemiol. Jan. 2010;31(1):99-101. [pmid: 19951203].
Boyce JM, Havill NL, Otter JA, et al. Impact of hydrogen peroxide vapor room decontamination on Clostridium difficile environmental contamination and transmission in a healthcare setting. Infection Control & Hospital Epidemiology. Aug. 1. 2008;29(8):723-30. [pmid: 18636950].
Carling PC, Briggs JL, Perkins J, et al. Improved cleaning of patient rooms using a new targeting method. Clin Infect Dis. Feb. 1. 2006;42(3):385-8. [pmid: 16392086].
Cooper RA, Griffith CJ, Malik RE, et al. Monitoring the effectiveness of cleaning in four British hospitals. Am J Infect Control. Jun. 2007;35(5):338-41. [pmid: 17577482].
De Angelis G, Cataldo MA, De Waure C, et al. Infection control and prevention measures to reduce the spread of vancomycin-resistant enterococci in hospitalized patients: a systematic review and meta-analysis. J Antimicrob Chemother. May. 2014;69(5):1185-92. [pmid: 24458513].
Dharan S, Mourouga P, Copin P, et al. Routine disinfection of patients' environmental surfaces. Myth or reality?. J Hosp Infect. Jun. 1999;42(2):113-7. [pmid: 10389060].
French GL, Otter JA, Shannon KP, et al. Tackling contamination of the hospital environment by methicillin-resistant Staphylococcus aureus (MRSA): A comparison between conventional terminal cleaning and hydrogen peroxide vapour decontamination. J Hosp Infect. May. 2004;57(1):31-7. [pmid: 15142713].
Halcomb EJ, Griffiths R, Fernandez R. Role of MRSA reservoirs in the acute care setting. Int J Evid Based Healthc. Mar. 2008;6(1):50-77. [pmid: 21631814].
Lewis T, Griffith C, Gallo M, et al. A modified ATP benchmark for evaluating the cleaning of some hospital environmental surfaces. J Hosp Infect. Jun. 2008;69(2):156-63. [pmid: 18468725].
Mayfield JL, Leet T, Miller J, et al. Environmental control to reduce transmission of Clostridium difficile. Clin Infect Dis. 2000;31(4):995-1000. [pmid: 11049782].
Moore G, Smyth D, Singleton J, et al. The use of adenosine triphosphate bioluminescence to assess the efficacy of a modified cleaning program implemented within an intensive care setting. Am J Infect Control. Oct. 2010;38(8):617-22. [pmid: 20605265].
Rupp ME, Huerta T, Cavalier RJ, et al. Optimum outlier model for potential improvement of environmental cleaning and disinfection. Infect Control Hosp Epidemiol. Jun. 2014;35(6):721-3. [pmid: 24799650].
Shapey S, Machin K, Levi K, et al. Activity of a dry mist hydrogen peroxide system against environmental Clostridium difficile contamination in elderly care wards. J Hosp Infect. Oct. 2008;70(2):136-41. [pmid: 18694613].
Sherlock O, O'Connell N, Creamer E, et al. Is it really clean? An evaluation of the efficacy of four methods for determining hospital cleanliness. J Hosp Infect. Jun. 2009;72(2):140-6. [pmid: 19321226].
Smith PW, Sayles H, Hewlett A, et al. A study of three methods for assessment of hospital environmental cleaning. Healthc Infect. Jun. 2013;18(2):80-5. http://dx.doi.org/10.1071/HI13001.

## Not a population of interest

Giannini MA, Nance D, McCullers JA. Are toilet seats a vector for transmission of methicillin-resistant Staphylococcus aureus?. Am J Infect Control. Aug. 2009;37(6):505-6. [pmid: 19243856].

## Not a pathogen of interest

Carling PC, Perkins J, Ferguson J, et al. Evaluating a new paradigm for comparing surface disinfection in clinical practice. Infect Control Hosp Epidemiol. Nov. 1. 2014;35(11):1349-55. http://dx.doi.org/10.1086/678424. [pmid: 25333429].
O'Neill C, Speziale P, Blue J, et al. Evaluation of ATP bioluminescence measuring system for monitoring hospital discharge cleaning. Can J Infect Control. Mar. 1. 2013;28(1):9-12.
Yahya MT, Cassells JM, Straub TM, et al. Reduction of microbial aerosols by automatic toilet bowl cleaners. J Environ Health. 1992;55(3):32-4.

## Does not address a key question

Recommendations for preventing the spread of vancomycin resistance. Recommendations of the Hospital Infection Control Practices Advisory Committee (HICPAC). MMWR Recomm Rep. Sep. 22. 1995;44(RR-12):1-13. [pmid: 7639408].
Attaway HH III, Fairey S, Steed LL, et al. Intrinsic bacterial burden associated with intensive care unit hospital beds: Effects of disinfection on population recovery and mitigation of potential infection risk. Am J Infect Control. Dec. 2012;40(10):907-12. [pmid: 22361357].
Backman C, Taylor G, Sales A, et al. An integrative review of infection prevention and control programs for multidrug-resistant organisms in acute care hospitals: A socio-ecological perspective. Am J Infect Control. Jun. 2011;39(5):368-78. [pmid: 21429622].
Bialachowski A, Clinker K, LeBlanc M, et al. The audit process: Part I. Pre-audit preparation. Can J Infect Control. Spring. 2010;25(1):68-70. [pmid: 20469658].
Bogusz A, Stewart M, Hunter J, et al. How quickly do hospital surfaces become contaminated after detergent cleaning?. Healthc Infect. 2013;18(1):3-9.
Bryce EA, Scharf S, Walker M, et al. The infection control audit: The standardized audit as a tool for change. Am J Infect Control. May. 2007;35(4):271-83. [pmid: 17483000].
Calfee DP, Salgado CD, Milstone AM, et al. Strategies to prevent Methicillin-resistant Staphylococcus aureus transmission and infection in acute care hospitals: 2014 update. Infect Control Hosp Epidemiol. Jul. 2014;35(7):772-96. [pmid: 24915205].
Cesarotti V, Di Silvio B. Quality management standards for facility services in the Italian health care sector. Int J Health Care Qual Assur Inc Leadersh Health Serv. 2006;19(6):451-62. [pmid: 17100217].
Coia JE, Duckworth GJ, Edwards DI, et al. Guidelines for the control and prevention of methicillin-resistant Staphylococcus aureus (MRSA) in healthcare facilities. J Hosp Infect. May. 2006;63:1-44. [pmid: 16517005].
Czerw AI, Kowalska M, Religioni U. Differences in the use of outsourcing in public and private institutions providing medical services. Arch Med Sci. Jun. 2014;10(3):618-29. [pmid: 25097595].
De Bono S, Heling G, Borg MA. Organizational culture and its implications for infection prevention and control in healthcare institutions. J Hosp Infect. Jan. 2014;86(1):1-6. [pmid: 24309419].
Ensuring cleaner hospitals. Health Estate. Sep. 2007;61(8):89-92. [pmid: 17892065].
Ferreira TG, Barbosa TF, Teixeira FL, et al. Effect of hospital disinfectants on spores of clinical Brazilian Clostridium difficile strains. ANAEROBE. Aug. 2013;22:121-2. Epub 2013 May 2. [pmid: 23644034].
Flanagan ME, Welsh CA, Kiess C, et al. A national collaborative for reducing health care-associated infections: Current initiatives, challenges, and opportunities. Am J Infect Control. Oct. 2011;39(8):685-9. [pmid: 21665329].
Gravel D, Gardam M, Taylor G, et al. Infection control practices related to Clostridium difficile infection in acute care hospitals in Canada. Am J Infect Control. Feb. 2009;37(1):9-14. [pmid: 19171246].
Halcomb EJ, Fernandez R, Griffiths R, et al. The infection control management of MRSA in acute care. Int J Evid Based Healthc. Dec. 2008;6(4):440-67. [pmid: 21631837].
Havill NL, Havill HL, Mangione E, et al. Cleanliness of portable medical equipment disinfected by nursing staff. Am J Infect Control. Sep. 2011;39(7):602-4. [pmid: 21496956].
Huskins WC. Interventions to prevent transmission of antimicrobial-resistant bacteria in the intensive care unit. Curr Opin Crit Care. Oct. 2007;13(5):572-7. [pmid: 17762238].
Kassem II, Esseili MA, Sigler V. Detection and differentiation of staphylococcal contamination of clinical surfaces using denaturing gradient gel electrophoresis. J Hosp Infect. Jul. 2011;78(3):187-93. [pmid: 21429621].
Lai KK, Kelley AL, Melvin ZS, et al. Failure to eradicate vancomycin-resistant enterococci in a university hospital and the cost of barrier precautions. Infect Control Hosp Epidemiol. Sep. 1998;19(9):647-52. [pmid: 9778162].
Lemmen SW, Zolldann D, Gastmeier P, et al. Implementing and evaluating a rotating surveillance system and infection control guidelines in 4 intensive care units. Am J Infect Control. 2001;29(2):89-93. [pmid: 11287875].
Loveday HP, Pellowe CM, Jones SR, et al. A systematic review of the evidence for interventions for the prevention and control of meticillin-resistant Staphylococcus aureus (1996-2004): report to the Joint MRSA Working Party (Subgroup A). J Hosp Infect. May. 2006;63:45-70. [pmid: 16616800].
Mermel LA, Jefferson J, Blanchard K, et al. Reducing Clostridium difficile incidence, colectomies, and mortality in the hospital setting: a successful multidisciplinary approach. Jt Comm J Qual Patient Saf. Jul. 2013;39(7):298-305. [pmid: 23888639].
Mokabel F, Hamer S, Collings L. Infection control activities in six hospitals: a comparison. Nurs Stand. Jan 28-Feb 3. 1998;12(19):34-8. [pmid: 9511704].
Moody J, Septimus E, Hickok J, et al. Infection prevention practices in adult intensive care units in a large community hospital system after implementing strategies to reduce health care-associated, methicillin-resistant Staphylococcus aureus infections. Am J Infect Control. Feb. 2013;41(2):126-30. [pmid: 22748841].
Mutters NT, Mersch-Sundermann V, Mutters R, et al. Control of the spread of vancomycin-resistant enterococci in hospitals: Epidemiology and clinical relevance. Dtsch Arztebl Int. Oct. 25. 2013;110(43):725-31. [pmid: 24222791].
Perlin JB, Hickok JD, Septimus EJ, et al. A bundled approach to reduce methicillin-resistant Staphylococcus aureus infections in a system of community hospitals. J Healthc Qual. May-Jun. 2013;35(3):57-68. [pmid: 23648079].
Popovich KJ, Hota B, Hayes R, et al. Effectiveness of routine patient cleansing with chlorhexidine gluconate for infection prevention in the medical intensive care unit. Infect Control Hosp Epidemiol. Oct. 2009;30(10):959-63. [pmid: 19712033].
Ramphal L, Sumhiro S, McCracken IM, et al. Improving hospital staff compliance with environmental cleaning behavior. Baylor University Medical Center Proceedings. Apr. 1. 2014;27(2):88-92. [pmid: 24688183].
Reshamwala A, McBroom K, Choi YI, et al. Microbial colonization of electrocardiographic telemetry systems before and after cleaning. Am J Crit Care. 2013;22(5):382-9. [pmid: 23996417].
Ross B, Hansen D, Popp W. Cleaning and disinfection in outbreak control - Experiences with different pathogens. Healthc Infect. 2013;18(1):37-41.
Rutala WA, Gergen MF, Sickbert-Bennett EE, et al. Effectiveness of improved hydrogen peroxide in decontaminating privacy curtains contaminated with multidrug-resistant pathogens. Am J Infect Control. Apr. 2014;42(4):426-8. [pmid: 24679570].
Rutala WA, Gergen MF, Weber DJ. Microbiologic evaluation of microfiber mops for surface disinfection. Am J Infect Control. Nov. 2007;35(9):569-73. [pmid: 17980233].
Salaripour M, McKernan P, Devlin R. A multidisciplinary approach to reducing outbreaks and nosocomial MRSA in a university-affiliated hospital. Healthc Q. Oct. 2006:54-60. [pmid: 17087169].
Samuelsson A, Jonasson J, Monstein HJ, et al. Clustering of enterococcal infections in a general intensive care unit. J Hosp Infect. Jul. 2003;54(3):188-95. [pmid: 12855233].
Sax H, Clack L, Touveneau S, et al. Implementation of infection control best practice in intensive care units throughout Europe: a mixed-method evaluation study. Implement Sci. Feb. 19. 2013;8:24. [pmid: 23421909].
Schelenz S, Tucker D, Georgeu C, et al. Significant reduction of endemic MRSA acquisition and infection in cardiothoracic patients by means of an enhanced targeted infection control programme. J Hosp Infect. Jun. 2005;60(2):104-10. [pmid: 15866007].
Sciortino CV, Giles RA. Validation and comparison of three adenosine triphosphate luminometers for monitoring hospital surface sanitization: A Rosetta Stone for adenosine triphosphate testing. Am J Infect Control. Oct. 2012;40(8):e233-e239. [pmid: 23021416].
Simoens S, Ophals E, Schuermans A. Search and destroy policy for methicillin-resistant Staphylococcus aureus: cost-benefit analysis. J Adv Nurs. Sep. 2009;65(9):1853-9. [pmid: 19694848].
Tomiczek A, Stumpo C, Downey JF. Enhancing patient safety through the management of Clostridium difficile at Toronto East General Hospital. Healthc Q. Oct. 2006:50-3. [pmid: 17087168].
White LF, Dancer SJ, Robertson C. A microbiological evaluation of hospital cleaning methods. Int J Environ Health Res. Aug. 2007;17(4):285-95. [pmid: 17613092].
Williams VR, Callery S, Vearncombe M, et al. Utility of environmental sampling for the prevention of transmission of vancomycin resistant enterococci (VRE) in hospitals. Can J Infect Control. Summer. 2009;24(2):119-24. [pmid: 19697537].
Wright SB, Ostrowsky B, Fishman N, et al. Expanding roles of healthcare epidemiology and infection control in spite of limited resources and compensation. Infect Control Hosp Epidemiol. Feb. 2010;31(2):127-32. [pmid: 20039800].
Zhang A, Nerandzic MM, Kundrapu S, et al. Does organic material on hospital surfaces reduce the effectiveness of hypochlorite and UV radiation for disinfection of clostridium difficile?. Infect Control Hosp Epidemiol. Oct. 2013;34(10):1106-8. [pmid: 24018930].