# Literature Search Methods

## Electronic Database Searches

ECRI Institute information specialists searched the following databases for relevant information. Search terms and strategies for the bibliographic databases appear below.

Table A-1 Electronic database searches

Database | Date Limits | Platform/Provider
ClinicalTrials.gov | Through February 3, 2015 | U.S. National Institutes of Health (http://www.clinicaltrials.gov/)
The Cochrane Central Register of Controlled Trials (CENTRAL) | 1990 through 2015. Issue 2 | Wiley
The Cochrane Database of Methodology Reviews (Methodology Reviews) | 1990 through 2015, Issue 2 | Wiley
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | 1990 through 2015, Issue 2 | Wiley
Cumulative Index to Nursing and Allied Health Literature (CINAHL) | 1990 through 2015, Issue 2 | EBSCOhost
Database of Abstracts of Reviews of Effects (DARE) | 1990 through 2015, Issue 2 | Wiley
EMBASE (Excerpta Medica) | 1990 through February 2, 2015 | Elsevier
Health Technology Assessment (HTA)Database | 1990 through 2015, Issue 2 | Wiley
Healthcare Standards Directory (ECRI Institute) | Through February 3, 2015 | ECRI Institute
MEDLINE (via EMBASE) | 1990 through February 2, 2015 | Elsevier
PubMed (In-process, Publisher, and PubMedNotMedline records) | 1990 through February 2, 2015 | U.S. National (http://www.pubmed.gov/) Library of Medicine
Scopus^*^ | Through February 4, 2015 | Elsevier
U.K. National Health Service Economic Evaluation Database (NHS EED) | 1990 through 2015, Issue 2 | Wiley
U.S. National Guideline Clearinghouse™ (NGC) | Through February 3, 2015 | Agency for Healthcare Research and Quality (AHRQ) (http://www.ngc.gov/)

* Scopus was utilized for citation tracking and searching trade publications

## Hand Searches of Journal and Non-journal Literature

Journals and supplements maintained in ECRI Institute's collections were routinely reviewed. Non-journal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature. See the Methods section, B. Gray Literature Search, for a list of gray literature resources searched.)

## Bibliographic Database Searches

### EMTREE Index Terms, CINAHL Headings, and Text Words

The search strategies employed combinations of free-text keywords as well as controlled vocabulary terms, including the concepts shown in the Topic-specific Search Terms table.

Table A-2 Topic-specific search terms

Concept | Controlled Vocabulary | Text Words
Population (admitted, adult patients in hospital settings) | EMTREE (EMBASE) Patient CINAHL Patients | Inpatient/s Patient/s
Setting (physical location) (patient rooms and common areas in hospitals and hospital-like settings) | EMTREE Health care facility Hospital Hospital discharge CINAHL Academic medical centers Health facilities Hospital units Hospitals Patients' rooms+ Patient discharge | Acute care Burn unit/s Common area/s Critical care General ward/s Health care facility/ies Healthcare facility/ies Health care setting/s Healthcare setting/s Hospital/s Hospitals/hospitalization ICU Institution/s Intensive care Medical facility/ies Medical ward/s Patient care area/s Patient room/s Patient ward/s
Setting (types of surfaces) (high-touch surfaces) | EMTREE Fomite Hospital bed Hospital equipment CINAHL “beds and mattresses” portable equipment | Bathroom* Bed rail/s Bedrail/s Cart/s Chair/s Clinical surfaces Commode/s Environmental surfaces Fomes Fomite/s Environmental réservoir/s High-contact High-touch Hospital bed/s Hospital surface/s Mobile equipment Portable equipment Railing/s Shared medical equipment Surface contamination Surface microbes Toilet* Wheelchair/s
Infections (broad terms) | EMTREE Healthcare associated infection Hospital infection CINAHL Cross infection | HAI/s Health care acquired infection/s Health care acquired pathogen/s Health care associated infection/s Health care associated pathogen/s Health care acquired infection/s Health care acquired pathogen/s Health care associated infection/s Health care associated pathogen/s Hospital acquired infection/s Hospital associated infection/s Hospital associated pathogen Health care acquired pathogen Healthcare acquired pathogen Hospital acquired pathogen/s Hospital associated pathogen/s
Infections (specific terms) (Clostridium difficile, methicillin-resistant Staphylococcus aureus, and vancomycin-resistant enterococci) | EMTREE Clostridium difficile Clostridium difficile infection Enterococcal infection Methicillin resistant staphylococcus aureus Methicillin resistant staphylococcus aureus infection Vancomycin resistant enterococcus CINAHL Clostridium difficile Clostridium infections Enterococcus Enterococcal infections Methicillin resistance Methicillin-resistant staphylococcus aureus Staphylococcal infections Vancomycin resistance | Antibiotic resistance Antibiotic-resistant CDI Difficile Methicillin-resistance Methicillin –resistant MRSA Multi-drug resistance Multi-drug-resistant Multidrug resistance Multidrug-resistant Vancomycin resistance Vancomycin-resistant VRE VRE
General hospital cleaning | EMTREE Cleaning disinfection environmental sanitation Infection control CINAHL Decontamination, hazardous materials Infection control Sterilization and disinfection | Cleaning Aseptic technique/s Cleaning method/s Cleaning practice/s Cleaning protocol/s Cleaning regimen/s Cleaning routines Cleaning technique/s Discharge cleaning Discharge room cleaning Enhanced cleaning Environmental cleaning Environmental decontamination Environmental disinfection Environmental sanitation Hospital hygiene Housekeeping Precleaning Pre-cleaning Room cleaning Room decontamination Routine cleaning Surface cleaning Surface decontamination Surface disinfection Terminal cleaning Terminal disinfection Terminal room
Disinfection agents | EMTREE Bleaching agent Disinfectant agent Quaternary ammonium derivative CINAHL Cleaning compounds Disinfectants Quaternary ammonium compounds Sodium hypochlorite | Accelerated hydrogen peroxide Aldehyde/s Alcohol/s Benzalkonium chloride Biocidal Biocide/s Bleach/ing Calcium hypochlorite Chemical agent/s Chemical disinfection Chlorhexidine digluconate Cleaning agent/s Disinfectant/s Disinfecting Disinfection agent/s Germicidal Germicide/s Glutaraldehyde Guanidine hydrochloride Hypochlorite/s Ortho-phthalaldehyde Orthophthalaldehyde Peracetic acid Phenol Phenols Phenolic/s QAC/s Quaternary ammonium Sodium dichloroisocyanurate Sporicidal Sporicide/s Vinegar
Automated devices | EMTREE Disinfection system Hydrogen peroxide Ultraviolet irradiation Ultraviolet radiation Vapor Water vapor CINAHL Hydrogen peroxide Ultraviolet rays | Aerosol Automated cleaning Automated device/s Automated decontamination Automated disinfection Automated surface Fogging Hydrogen peroxide H2O2 Mist No-touch Non-touch Pulsed ultrasound Pulsed xenon Room sterilisation Room sterilization Self-disinfecting Self disinfection Steam Superoxidis/zed water Ultraviolet disinfection Ultraviolet irradiation Ultraviolet light Ultraviolet radiation UV disinfection UV irradiation UV light UV radiation Vapor/ization Vapour/isation 405-nm 405nm
Enhanced coatings and surfaces | EMTREE Copper Material coating CINAHL Copper | Antimicrobial coating/s Antimicrobial-impregnated Antimicrobial surface/s Coated Coating/s Copper-coated Copper-impregnated Copper surface/s Silver-coated Silver-impregnated Silver surface/s
Cleaning personnel and training | EMTREE Hospital service Housekeeping Staff training CINAHL Education Housekeeping department Staff development | Cleaning personnel Cleaning service/s Cleaning staff Cleaning worker/s Environmental services Environmental technician/s Housekeeper/s Housekeeping Service worker/s Staff
Measuring and monitoring cleanliness | EMTREE Adenosine triphosphate Bioluminescence Hospital hygiene CINAHL Adenosine triphosphate Luminescent measurements | Adenosine triphosphate ATP Bioluminescence Cleanliness Fluorescent marker/s Glo-germ Glogerm Hospital hygiene Surface hygiene

### Search Strategies

The strategy below is presented in EMBASE syntax; the search was simultaneously conducted across EMBASE and MEDLINE. A similar strategy was used to search the databases comprising CINAHL, the Cochrane Library, and PubMed.

Table A-3 EMBASE/MEDLINE strategy

Set # | Concept | Search Statement
1 | Infections (broad terms, healthcare-associated) | (“healthcare associated infection” OR “hospital infection”)/de
2 | Infections (broad terms, healthcare-associated) | ((“health care acquired” next/1 (infection* OR pathogen*)) OR (“healthcare acquired” next/1 (infection* OR pathogen*)) OR (“hospital acquired” next/1 (infection* OR pathogen*)) OR (“health care associated” next/1 (infection* OR pathogen*)) OR (“healthcare associated” next/1 (infection* OR pathogen*)) OR (“hospital associated” next/1 (infection* OR pathogen*))):ti,ab
3 | Infections (broad terms, healthcare-associated) | (HAI OR HAIs):ti
4 | Infections (specific terms-bacterial) | (“clostridium difficile” OR “clostridium difficile infection” OR “methicillin resistant staphylococcus aureus” OR “methicillin resistant staphylococcus aureus infection” OR enterococcus OR “vancomycin resistant enterococcus” OR “enterococcal infection”)/de
5 | Infections (specific terms-bacterial) | ((antibiotic OR “multi-drug” OR multidrug OR methicillin OR vancomycin) next/1 resistan*):ti,ab OR difficile:ti,ab OR (“methicillin resistant” next/2 aureus):ti,ab OR (“vancomycin resistant” next/1 enterococc*):ti,ab
6 | Infections (specific terms-bacterial) | (CDI OR MRSA OR VRE):ti
7 | Limit to patients | (#4 OR #5 OR #6) AND (patient/exp OR (inpatient* OR patient*):ti,ab)
8 | Combine infection sets | #1 OR #2 OR #3 OR #7
9 | Setting (hospitals, inpatient facilities, patient rooms) | (“health care facility” OR “hospital discharge”)/de OR hospital/exp
10 | Setting (hospitals, inpatient facilities, patient rooms) | (“acute care” OR “burn unit” OR “burn units” OR “common area” OR “common areas” OR “critical care” OR “healthcare facility” OR “healthcare facilities” OR “health care facility” OR “health care facilities” OR “healthcare setting” OR “healthcare settings” OR “health care setting” OR “health care settings” OR hospital OR hospitalis* OR hospitaliz* OR ICU OR institution OR institutions OR “intensive care” OR “patient care area” OR “medical facility” OR “medical facilities” OR “patient care areas” OR “patient room” OR “patient rooms” OR “patients rooms” OR ward OR wards):ti,ab
11 | Setting (high-touch surfaces) | (fomite OR “hospital bed” OR “hospital equipment”)/de
12 | Setting (high-touch surfaces) | (fomes OR fomite* OR “environmental reservoir” OR “environmental reservoirs” OR “surface contamination” OR “surface microbes”):ti,ab
13 | Setting (high-touch surfaces) | (bathroom* OR “bed rail” OR “bed rails” OR bedrail* OR cart OR carts OR chair OR chairs OR “clinical surfaces” OR commode* OR “environmental surfaces” OR “high contact” OR “high-touch” OR “hospital bed” OR “hospital beds” OR “hospital surfaces” OR “mobile equipment” OR “portable medical equipment” OR railing OR railings OR toilet* OR “shared medical equipment” OR wheelchair*):ti,ab
14 | Combine setting sets | #9 OR #10 OR #11 OR #12 OR #13
15 | Combine sets (any infection or setting) | #8 OR #14
16 | General cleaning | (cleaning OR disinfection OR “environmental sanitation”)/de OR “infection control”/mj
17 | General cleaning | (“cleaning method” OR “cleaning methods” OR “cleaning practice” OR “cleaning practices” OR “cleaning protocol” OR “cleaning protocols” OR “cleaning regimen” OR “cleaning regimens” OR “cleaning routines” OR “cleaning technique” OR “cleaning techniques” OR “discharge cleaning” OR “discharge room cleaning” OR “enhanced cleaning” OR “environmental cleaning” OR “environmental decontamination” OR “environmental disinfection” OR “environmental sanitation” OR “hospital cleaning” OR “pre cleaning” OR precleaning OR “room cleaning” OR “room decontamination” OR “routine cleaning” OR “surface cleaning” OR “surface disinfection” OR “surface decontamination” OR “terminal cleaning” OR “terminal disinfection” OR “terminal room”):ti,ab
18 | General cleaning | (cleaning OR decontamination OR disinfect* OR “infection control”):ti
19 | Disinfectants | “disinfectant agent”/exp OR (“bleaching agent” OR “quaternary ammonium derivative”/de)
20 | Disinfectants | (biocidal OR biocide* OR “chemical agent” OR “chemical agents” OR “chemical disinfection” OR “cleaning agent” OR “cleaning agents” OR disinfectant* OR “disinfecting agent” OR “disinfecting agents” OR “disinfection agent” OR “disinfection agents” OR germicidal OR germicide* OR sporicidal OR sporicide*):ti,ab
21 | Disinfectants | (“accelerated hydrogen peroxide” OR aldehyde* OR alcohol OR alcohols OR bleach OR bleaching OR “benzalkonium chloride” OR “calcium hypochlorite” OR “chlorhexidine digluconate” OR glutaraldehyde OR “guanidine hydrochloride” OR hypochlorite* OR “ortho-phthalaldehyde” OR orthophthalaldehyde OR “peracetic acid” OR phenolic* OR phenol OR phenols OR “quaternary ammonium” OR QACs OR “sodium dichloroisocyanurate” OR “sodium hypochlorite” OR vinegar):ti,ab
22 | Limit to disinfectant studies to cleaning | (#19 OR #20 OR #21) AND (clean* OR decontaminat* OR disinfect* OR housekeep*):ti,ab
23 | Automated devices | (“disinfection system” OR “ultraviolet irradiation” OR “ultraviolet radiation”)/de OR (“hydrogen peroxide” AND (vapor OR “water vapor”))/de
24 | Automated devices | (automated next/2 (cleaning OR device* OR decontamination OR disinfection)):ti,ab OR ((“no touch” OR “non touch”) next/1 disinfect*):ti,ab OR (“room sterilisation” OR “room sterilization” OR “self disinfecting”):ti,ab
25 | Automated devices | ((405nm OR “405 nm” OR “pulsed ultrasound” OR “pulsed xenon” OR ((ultraviolet OR UV) next/1 (disinfection OR light OR irradiation OR radiation))):ti,ab) AND (clean* OR decontaminat* OR disinfect* OR room OR rooms):ti,ab
26 | Automated devices | “superoxidised water”:ti,ab OR “superoxidized water”:ti,ab OR ((“hydrogen peroxide” OR H2O2) AND (aerosol* OR fogging OR mist OR steam OR system OR systems OR vapor* OR vapour*)):ti,ab
27 | Enhanced coatings and surfaces | (copper AND “material coating”)/de
28 | Enhanced coatings and surfaces | “self disinfecting”:ti,ab OR ((antimicrobial OR copper OR silver) NEAR/2 (coated OR coating* OR impregnated OR surface*)):ti,ab
29 | Cleaning personnel and training | (“hospital service” OR housekeeping OR “staff training”)/de
30 | Cleaning personnel and training | (“cleaning personnel” OR “cleaning service” OR “cleaning services” OR “cleaning staff” OR “cleaning workers” OR “environmental services” OR “environmental technician” OR “environmental technicians” OR housekeeper* OR housekeeping OR “service worker” OR “service workers”):ti,ab
31 | Measuring and monitoring cleanliness | (“adenosine triphosphate” AND bioluminescence)/de OR (“hospital hygiene”)/de
32 | Measuring and monitoring cleanliness | (((“adenosine triphosphate” OR ATP) next/1 bioluminescen*) OR cleanliness OR “fluorescent marker” OR “fluorescent markers” OR “glo germ” OR glogerm OR “hospital hygiene” OR “surface hygiene”):ti,ab
33 | Combine sets (any cleaning concept) | #16 OR #17 OR #18 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32
34 | Combine sets (any infection or setting AND any cleaning concept) | #15 AND #33
35 | Limit to English-language publications | #34 AND [english]/lim
36 | Remove undesired publication types | #35 NOT (‘conference paper’/exp OR (‘case report’ OR book OR erratum OR letter OR note OR ‘short survey’)/de OR (book OR conference OR erratum OR letter OR note OR ‘short survey’):it OR (book OR ‘conference proceeding’):pt)
37 | Limit to publications with abstracts | #36 AND [abstracts]/lim
38 | Remove animal and in vitro studies | #37 NOT ([animal cell]/lim OR [animal experiment]/lim OR [animal model]/lim OR [animal tissue]/lim OR “in vitro study”/de)
39 | Remove pediatric studies | #38 NOT (adolescen* OR babies OR child* OR fetal OR infant OR infants OR neonat* OR newborn* OR NICU OR paediatric* OR pediatric* OR school OR schools OR teen* OR youth*):ti
40 | Remove undesired geographic locations | #39 NOT (africa/exp OR asia/exp OR mexico/de OR “oceanic regions”/exp OR “south and central america”/exp)
41 | Limit by publication date | #40 AND [1990-2015]/py
42 | Limit to meta-analyses and systematic reviews published | #41 AND (“meta analysis”/de OR “systematic review”/de OR (“evidence base” OR “evidence based” OR “meta analysis” OR methodologic* OR pooled OR “quantitative analysis” OR “quantitative review” OR “research synthesis” OR search* OR “systematic review”):ti,ab)
43 | Limit to clinical studies | #41 AND ((“comparative study” OR “controlled study” OR “experimental study” OR “field study” OR “in vivo study” OR methodology OR model OR “observational study” OR “pilot study” OR “prevention study” OR “quasi experimental study” OR “trend study” OR “validation study”)/exp OR (analysis OR “case control” OR clinical OR cohort OR comparison OR “matched controls” OR random* OR study OR trial):ti,ab OR article/de OR article:it OR “article in press”:it OR “priority journal”/de)
44 | Limit to narrative reviews published from 2009 onward | #41 AND (review/de OR review:it OR (overview OR review):ti) AND [2009-2015]/py
45 | Limit to clinical practice guidelines | #41 AND (practice guideline/exp OR (“best practice” OR “best practices” OR consensus OR guidance OR guideline* OR recommendation* OR standard* OR statement):ti)
46 | Combine sets | #42 OR #43 OR #44 OR #45

EMBASE Syntax

* | = truncation character (wildcard)
NEAR/n | = search terms within a specified number (n) of words from each other in any order
NEXT/n | = search terms within a specified number (n) of words from each other in the order specified
/ | = search as a subject heading
exp | = “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary's hierarchy)
mj | = denotes a term that has been searched as a major subject heading
/de | = search in the descriptors field (controlled terms and keywords)
:lnk | = floating subheading
:it,pt. | = source item or publication type
:ti. | = limit to title
:ti,ab. | = limit to title and abstract fields