# Summary and Implications (GQ 4)

The focus of this Technical Brief is those with a history of repeated psychiatric admissions or who are identified as being at high risk of psychiatric rehospitalization. This approach excluded much literature that tested these strategies but did not target our population of interest. Accordingly, this brief cannot be considered a comprehensive review of any of the individual management strategies discussed, but it does ensure that our findings are applicable to those at risk of repeated psychiatric hospitalization.

At the same time, there has been a substantial effort to research this area because the amount of relevant literature identified by this focused search was surprisingly large—63 studies reported in 76 articles for GQ 3 alone, with the most data on Assertive Community Treatment (ACT), involuntary outpatient commitment (OPC)/compulsory treatment orders (CTOs), and intensive case management (ICM)—suggesting that important gaps in the evidence base remain.

## Key Issues That May Affect Diffusion of Strategies

### Ethics and Privacy

Ethical considerations may influence the frequency of use of OPC/CTO. Mental health consumers and providers of services hold varying beliefs as to when and if the benefits of OPC/CTO are substantial enough to restrict an individual’s civil liberties by compelling treatment, perhaps for extended periods in the community.66,69,70,72,88,138 Of note, we found no articles directly addressing privacy issues, and Key Informants (KIs) did not stress this as a theme.

### Equity

Not all the potentially beneficial management strategies discussed in this brief are universally available, and they often exist in somewhat different forms depending on setting (including both geography and type of insurer). For example, ACT is resource intensive and not uniformly available across the United States or internationally. In the United States, only one insurer, Medicaid,139 typically pays for the intervention, and the potential impact of the increasing shift from conventional Medicaid plans to managed Medicaid programs is unknown. Further, varying laws can limit how certain strategies are applied and may limit their effectiveness. OPC and CTOs exist in different forms based on individual State and/or country-specific laws. For example, Canada and Australia allow forced medication as part of an outpatient order, whereas the United Kingdom and the United States do not; these legal variations may explain differing findings about the effectiveness of CTOs.66,70,72 Further, these challenges can hamper sustainability.

Also, effectiveness of strategies can be strongly dependent on the availability of local resources. In the case of CTOs, mandated treatment alone is not sufficient, given that the strategy is effective only if supporting mental health services are actually available in the community.72 Effectiveness can also require appropriate application. Clinicians may need to initiate legal renewals of CTOs to allow them to produce a clinically meaningful reduction in readmissions.71,72

### Costs

A key issue for costs is how to determine when psychiatric readmission is indicated and when not. Sometimes psychiatric readmissions are appropriate. In such instances, cost concerns risk limiting proper psychiatric admissions. The literature53,69 and KIs suggested that financial incentives are more likely to compete with ethical concerns when prospective payment systems are in place. Each noted that, from a clinical perspective, readmission is not necessarily something to avoid and, although potentially costly, may be justified for individuals because of the severity of their chronic and recurrent illnesses. Hence, a key consideration for reimbursement systems and for good quality of care delivery is to be able to account for when readmission is the correct outcome, one that should not be penalized.

At other times, intensive outpatient efforts may be able to successfully avoid rehospitalization, and here cost comparisons may be more reasonably compared. Studies assessing the costs associated with the various management strategies generally reported a reduction in cost, primarily due to the expense of inpatient care.24,40,46,50 One intensive case management study noted that even when taking into account the additional costs of intensive case management, the overall costs assumed by those individuals receiving care are decreased.50 Furthermore, although ACT is considered an expensive intervention, the savings from reduced inpatient costs are typically far greater, except when the standard service comparator is comprehensive and well resourced.40 Additionally, when comparing two different transition support services, one study found that although case management was more expensive than the standard community psychiatric nursing service approach, the improvement in other patient outcomes focused on patient well-being may be worth the additional cost.58

KIs highlighted a concern that the criteria for discharge are now overly reliant on legal and insurance systems rather than on the patient’s readiness for discharge. In other words, as soon as a psychiatrically hospitalized person is no longer considered an imminent risk to self or others, he or she is discharged, whether or not there is evidence that the individual can live successfully in the community. One KI suggested that a historical analysis of how postdischarge suicide rates have changed over time would be informative, given the general trend for shorter hospital stays over the past few decades. KIs also mentioned emerging strategies that are currently under investigation, such as Critical Time Interventions (a time-limited case management model designed to prevent recurrent homelessness in the serious mentally ill population) and alternative payment strategies that focus on quality of care rather than on the amount of service delivered.

#### Gaps in Evidence Base and Future Areas of Research

Our literature review and KI discussions highlighted key gaps in the evidence base. First, while there may be enough evidence to support a systematic review on the effectiveness of ACT in this population, in general, further research is needed to sort out the inconsistency of findings implied by the evidence map. Second, we found no studies that assessed the comparative effectiveness of the management strategies in addressing psychiatric readmissions, including a comparison of their relative advantages and disadvantages.

Third, we did not identify any studies that attempted to evaluate how the effectiveness of various strategies might vary by patient characteristics, such as degree of severity or intractability of mental illness or the presence of coexisting medical conditions; by provider characteristics, such as a community mental health provider versus a tertiary care mental health provider; or by system variables, such as the availability of specific resources.

Fourth, we did not identify studies that assessed what factors might affect successful dissemination and implementation of these strategies. This information is important given the variability in available resources for putting these strategies into practice.

Fifth, our eligibility criteria required that the population have a history of at least two prior psychiatric hospitalizations or be clearly identified as a population at high risk of psychiatric readmission. This restriction allowed us to target our population of interest, but it also may have resulted in excluding potentially relevant studies of our included strategies that were applied to a broader population. Also, promising short-term alternatives to psychiatric rehospitalization (e.g., home-based services or Critical Time Intervention) not meeting our eligibility criteria would also not have been included.

Finally, none of the available studies assessed which particular components were most effective in improving outcomes, a key consideration when components of management strategies overlap and are interdependent and when resources are limited. Some studies noted that even when interventions are successful in reducing readmissions, the outcomes associated with specific factors or components,77,79 the length and duration of the intervention,45,56 and the effect of switching56 or stopping the intervention all remain unclear.45,56 Interventions should be clearly defined47 and take into account characteristics of the intervention and the setting in which it is being applied (e.g., caseloads, environmental and resource factors, location) that may affect outcomes.30,38,39,42,46

#### Other Considerations for Future Research

Several authors questioned whether their own research had targeted a specific and sufficiently stable population. Frequently readmitted patients may not always continue to be high users of inpatient hospitalization services, even without specific interventions;52 thus, more research is needed to identify specific variables associated with readmission.57 Such studies would require larger sample sizes to allow enough power to examine subpopulations.80 Some authors suggested separating out the treatment-resistant patients, especially those who are noncompliant and, thus, may respond differently to treatment.20,68

Research may need to broaden the population for whom these strategies are tested. The literature we identified focused nearly exclusively on those with primary psychotic disorders, with some involvement of those with bipolar illness, so most of the evidence is relevant for that population and less clearly for those with major depressive disorder, personality disorders, or substance use disorders. However, our background literature and KI interviews would suggest that the overall population of those at risk of repeated psychiatric hospitalization includes these other diagnoses.140

In concert with the limited evidence we found in the literature, KIs universally noted the lack of research systematically identifying or studying the definitive LOS necessary to ensure readiness for discharge and successful transition to the community. As a corollary to this significant evidence gap, several KIs pointed out the lack of information about how LOS affects risk of harm or safety issues (e.g., unintended consequences such as housing loss, job loss, school disruption, and financial costs leading to bankruptcy) as well as the lack of information on the potential benefits of increased LOS (increased ability to provide education regarding symptoms of illness, signs of recurrent episodes, and education about medications and the need for treatment adherence; education of family regarding the illness; more successful arrangement of housing; greater stabilization of suicidal ideation). Evidence-based decisions about LOS need to weigh these points.

### Implications

Effective management of as heterogeneous a population as those at high risk of readmission is effort intensive and challenging. The available information suggests that, beyond ACT for those individuals with serious mental illness, little data identify which strategies effectively reduce psychiatric readmission or LOS. As a consequence, the field needs more primary studies with direct comparisons of the potential strategies when possible.

Selecting a meaningful and accurate outcome is critical. Of the primary outcomes we considered for this brief, LOS in a hospital appears to more consistently identify an effective management strategy compared with standard care. Furthermore, LOS appears more meaningful than the number of readmissions or readmission rate, because for individuals with a diagnosis of serious mental illness who have a persistent and recurrent illness, in some cases hospitalization is a good outcome. As with medical illness, exacerbations can occur even in the presence of good and adequate care. Strategies can still be applied to minimize LOS and to effectively prepare for sustained outpatient care, but the occurrence of a repeated psychiatric hospitalization is not always an adverse event: it may be appropriate care. Hence, an important consideration for future research is to continue to measure LOS while also distinguishing between appropriate and inappropriate admissions.

The accuracy of these related psychiatric readmission outcomes (including LOS), however, is of concern. Although published literature did not address this issue directly, many studies discuss data limitations in light of the study design used and data collected. Use of administrative data to examine readmissions is subject to several caveats. Consistent with this view, the KIs noted that the accuracy of administrative data systems tracking hospital admissions varies by region. Sometimes only readmissions to the same unit (medical/surgical unit vs. psychiatric unit), same facility, a facility within the same organization/State, or paid by the same insurer are able to be tracked. Incomplete data on outcomes may bias results.

At the same time, outcomes not related directly to hospital readmissions or LOS might be more meaningful in determining the effectiveness of these management strategies. A key point identified by the KIs (and reflected in the literature) considered whether successful functioning in the community (reflected by adequate arrangement and continuity of outpatient care, housing stability, employment, being in a supportive climate), which indicates a readiness for discharge and return to the community, might comprise a more meaningful outcome measure.

The literature and KIs both indicate that the availability and implementation of these management strategies can vary substantially across the country, because of differences in State and local payment strategies, State policy, access to care, and resource availability. This variation can make it challenging to provide a consistent intervention (e.g., intensive case management in one locale may differ from that applied in another) and know how best to apply the strategy in a particular setting (e.g., resources available in one setting necessary for providing high-fidelity ACT may differ from those available in another). Dissemination and implementation research for evidence-based strategies could helpfully inform how a particular strategy might be best administered in a real world setting. Such information could inform policymakers who seek to optimize the benefits and tradeoffs of fidelity versus adaptation when planning for wide dissemination and uptake of evidence-based strategies.

Finally, these management strategies can be challenging to study. One key variable in this difficulty is that these strategies are not clearly mutually exclusive, and they do not exist in a vacuum from the community in which they are administered. These strategies appear to overlap and are likely to be interdependent. Our attempts to categorize them into exclusive categories (e.g., transition support service vs. short-term alternative to psychiatric rehospitalization) were somewhat artificial given their interdependence. Attempts at comparing the effectiveness of various combinations of these components (e.g., different packages of services) and how the implementation of those packages of selected components may be affected by locally available resources, could be informative.