# References

1 National Association of Psychiatric Health Systems. Medicare Psychiatric Patients and Readmissions in the Inpatient Psychiatric Facility Prospective Payment System. The Moran Company. 2013. https://www.naphs.org/resourcemanager/handlerresource.aspx?id=408. 2015 February 3.
2 Hines AL, Barrett ML, Jiang HJ, et al. Conditions With the Largest Number of Adult Hospital Readmissions by Payer, 2011. HCUP Statistical Brief #172. Rockville, MD. Agency for Healthcare Research and Quality. April. 2014. http://www.hcup-us.ahrq.gov/reports/statbriefs/sb172-Conditions-Readmissions-Payer.pdf.
3 Klinkenberg WD, Calsyn RJ. Predictors of receipt of aftercare and recidivism among persons with severe mental illness: a review. Psychiatr Serv. May. 1996;47(5):487-96. Epub: 1996/05/01. [pmid: 8740489].
4 Olfson M, Mechanic D, Boyer CA, et al. Assessing clinical predictions of early rehospitalization in schizophrenia. J Nerv Ment Dis. Dec. 1999;187(12):721-9. Epub: 2000/02/09. [pmid: 10665466].
5 Montgomery P, Kirkpatrick H. Understanding those who seek frequent psychiatric hospitalizations. Arch Psychiatr Nurs. Feb. 2002;16(1):16-24. Epub: 2002/03/06. [pmid: 11877602].
6 Medicare Psychiatric Patients & Readmissions in the Inpatient Psychiatric Facility Prospective Payment System. Prepared For:. National Association of Psychiatric Health Systems. 2013. May. https://www.naphs.org/resourcemanager/handlerresource.aspx?id=408. February 3 2015.
7 Williams P, Csipke E, Rose D, et al. Efficacy of a triage system to reduce length of hospital stay. Br J Psychiatry. 2014. Mar. 13. Epub: 2014/03/15. [pmid: 24627298].
8 National Association of Public Hospitals and Health Systems. Reducing Readmissions in Safety Net Hospitals and Health Systems. National Association of Public Hospitals and Health Systems. Research Brief. Washington, DC. 2011. http://essentialhospitals.org/wp-content/uploads/2014/09/Dec-2011-Readmissions-RB-Final.pdf.
9 Schmutte T, Dunn CL, Sledge WH. Predicting time to readmission in patients with recent histories of recurrent psychiatric hospitalization: a matched-control survival analysis. J Nerv Ment Dis. Dec. 2010;198(12):860-3. Epub: 2010/12/08. [pmid: 21135635].
10 Steffen S, Kosters M, Becker T, et al. Discharge planning in mental health care: a systematic review of the recent literature. Acta Psychiatr Scand. Jul. 2009;120(1):1-9. Epub: 2009/06/03. [pmid: 19486329].
11 Vigod SN, Kurdyak PA, Dennis CL, et al. Transitional interventions to reduce early psychiatric readmissions in adults: systematic review. Br J Psychiatry. Mar. 2013;202(3):187-94. Epub: 2013/03/05. [pmid: 23457182].
12 Viggiano T, Pincus HA, Crystal S. Care transition interventions in mental health. Curr Opin Psychiatry. Nov. 2012;25(6):551-8. Epub: 2012/09/21. [pmid: 22992544].
13 Ilgen MA, Hu KU, Moos RH, et al. Continuing care after inpatient psychiatric treatment for patients with psychiatric and substance use disorders. Psychiatr Serv. Sep. 2008;59(9):982-8. Epub: 2008/09/02. [pmid: 18757590].
14 Dieterich M, Irving CB, Park B, et al. Intensive case management for severe mental illness. Cochrane Database Syst Rev. 2010;(10):CD007906. Epub: 2010/10/12. [pmid: 20927766].
15 Marshall M, Lockwood A. Assertive community treatment for people with severe mental disorders. Cochrane Database Syst Rev. 2000;(2):CD001089. Epub: 2000/05/05. [pmid: 10796415].
16 Marshall M, Crowther R, Sledge WH, et al. Day hospital versus admission for acute psychiatric disorders. Cochrane Database Syst Rev. 2011;(12):CD004026. Epub: 2011/12/14. [pmid: 22161384].
17 Meehan J, Kapur N, Hunt IM, et al. Suicide in mental health in-patients and within 3 months of discharge. National clinical survey. Br J Psychiatry. Feb. 2006;188:129-34. Epub: 2006/02/02. [pmid: 16449699].
18 Babalola O, Gormez V, Alwan NA, et al. Length of hospitalisation for people with severe mental illness. Cochrane Database Syst Rev. 2014;1:CD000384. Epub: 2014/01/31. [pmid: 24477710].
19 Appleby L, Desai PN, Luchins DJ, et al. Length of stay and recidivism in schizophrenia: a study of public psychiatric hospital patients. Am J Psychiatry. Jan. 1993;150(1):72-6. Epub: 1993/01/01. [pmid: 8417584].
20 Appleby L, Luchins DJ, Desai PN, et al. Length of inpatient stay and recidivism among patients with schizophrenia. Psychiatr Serv. Sep. 1996;47(9):985-90. Epub: 1996/09/01. [pmid: 8875666].
21 Barekatain M, Maracy MR, Rajabi F, et al. Aftercare services for patients with severe mental disorder: A randomized controlled trial. J Res Med Sci. 2014;19(3):240-5. [pmid: 24949032].
22 Sharifi V, Tehranidoost M, Yunesian M, et al. Effectiveness of a low-intensity home-based aftercare for patients with severe mental disorders: a 12-month randomized controlled study. Community Ment Health J. Dec. 2012;48(6):766-70. Epub: 2012/07/10. [pmid: 22772746].
23 Lay B, Blank C, Lengler S, et al. Preventing compulsory admission to psychiatric inpatient care using psycho-education and monitoring: feasibility and outcomes after 12 months. Eur Arch Psychiatry Clin Neurosci. 2014. Nov. 1. Epub: 2014/11/02. [pmid: 25361537].
24 Schmidt-Kraepelin C, Janssen B, Gaebel W. Prevention of rehospitalization in schizophrenia: results of an integrated care project in Germany. Eur Arch Psychiatry Clin Neurosci. Nov. Suppl 2. 2009;259:S205-12. Epub: 2009/11/13. [pmid: 19876680].
25 Puschner B, Steffen S, Völker KA, et al. Needs-oriented discharge planning for high utilisers of psychiatric services: Multicentre randomised controlled trial. Epidemiol Psychiatr Sci. 2011;20(2):181-92. [pmid: 21714365].
26 Puschner B, Steffen S, Gaebel W, et al. Needs-oriented discharge planning and monitoring for high utilisers of psychiatric services (NODPAM): design and methods. BMC Health Serv Res. 2008;8:152. Epub: 2008/07/23. [pmid: 18644110].
27 Davies S, Fallow S, Bruce J, et al. Early outcomes of supervised discharge. Med Sci Law. Jan. 2001;41(1):31-4. Epub: 2001/02/24. [pmid: 11219120].
28 Davies S, Bruce J, Fallows S. Section 25 aftercare under supervision: the first eighteen months' experience. Med Sci Law. Jul. 1999;39(3):214-8. Epub: 1999/08/31. [pmid: 10466315].
29 Forchuk C, Martin ML, Chan YL, et al. Therapeutic relationships: from psychiatric hospital to community. J Psychiatr Ment Health Nurs. Oct. 2005;12(5):556-64. Epub: 2005/09/17. [pmid: 16164506].
30 Fenton WS, Mosher LR, Herrell JM, et al. Randomized trial of general hospital and residential alternative care for patients with severe and persistent mental illness. Am J Psychiatry. Apr. 1998;155(4):516-22. Epub: 1998/04/18. [pmid: 9545998].
31 Fenton WS, Hoch JS, Herrell JM, et al. Cost and cost-effectiveness of hospital vs residential crisis care for patients who have serious mental illness. Arch Gen Psychiatry. Apr. 2002;59(4):357-64. Epub: 2002/04/03. [pmid: 11926936].
32 Merchant DJ, Henfling PA. Scheduled brief admissions: patient "tuneups". J Psychosoc Nurs Ment Health Serv. Dec. 1994;32(12):7-10. Epub: 1994/12/01. [pmid: 7714856].
33 Dilonardo JD, Connelly CE, Gurel L, et al. Scheduled intermittent hospitalization for psychiatric patients. Psychiatr Serv. Apr. 1998;49(4):504-9. Epub: 1998/04/29. [pmid: 9550241].
34 Dincin J, Wasmer D, Witheridge TF, et al. Impact of assertive community treatment on the use of state hospital inpatient bed-days. Hosp Community Psychiatry. Sep. 1993;44(9):833-8. Epub: 1993/09/01. [pmid: 8225294].
35 Liem SK, Lee CC. Effectiveness of assertive community treatment in Hong Kong among patients with frequent hospital admissions. Psychiatr Serv. Nov. 1. 2013;64(11):1170-2. Epub: 2013/11/05. [pmid: 24185540].
36 Botha UA, Koen L, Joska JA, et al. Assessing the efficacy of a modified assertive community-based treatment programme in a developing country. BMC Psychiatry. 2010;10:73. Epub: 2010/09/17. [pmid: 20843301].
37 Stein LI, Test MA. Alternative to mental hospital treatment. I. Conceptual model, treatment program, and clinical evaluation. Arch Gen Psychiatry. Apr. 1980;37(4):392-7. Epub: 1980/04/01. [pmid: 7362425].
38 Bond GR, Witheridge TF, Dincin J, et al. Assertive community treatment for frequent users of psychiatric hospitals in a large city: a controlled study. Am J Community Psychol. Dec. 1990;18(6):865-91. Epub: 1990/12/01. [pmid: 2091459].
39 Bond GR, Pensec M, Dietzen L, et al. Intensive case management for frequent users of psychiatric hospitals in a large city: A comparison of team and individual caseloads. Psychosoc Rehab J. 1991;15(1):90-8.
40 Botha UA, Koen L, Galal U, et al. The rise of assertive community interventions in South Africa: A randomized control trial assessing the impact of a modified assertive intervention on readmission rates; a three year follow-up. BMC Psychiatry. 2014;14(1).
41 Dietzen LL, Bond GR. Relationship between case manager contact and outcome for frequently hospitalized psychiatric clients. Hosp Community Psychiatry. Sep. 1993;44(9):839-43. Epub: 1993/09/01. [pmid: 8225295].
42 Hamernik E, Pakenham KI. Assertive community treatment for persons with severe mental disorders: A controlled treatment outcome study. Behaviour Change. 1999;16(4):259-68.
43 Sytema S, Wunderink L, Bloemers W, et al. Assertive community treatment in the Netherlands: a randomized controlled trial. Acta Psychiatr Scand. Aug. 2007;116(2):105-12. Epub: 2007/07/26. [pmid: 17650271].
44 Tibbo P, Chue P, Wright E. Hospital outcome measures following assertive community treatment in Edmonton, Alberta. Can J Psychiatry. Apr. 1999;44(3):276-9. Epub: 1999/05/04. [pmid: 10225130].
45 Udechuku A, Olver J, Hallam K, et al. Assertive community treatment of the mentally ill: service model and effectiveness (Structured abstract). Australasian Psychiatry. 2005;13(2):129-34. [pmid: 15948908].
46 Kolbasovsky A. Reducing 30-day inpatient psychiatric recidivism and associated costs through intensive case management. Prof Case Manag. Mar-Apr. 2009;14(2):96-105. Epub: 2009/03/26. [pmid: 19318901].
47 Lichtenberg P, Levinson D, Sharshevsky Y, et al. Clinical case management of revolving door patients - a semi-randomized study. Acta Psychiatr Scand. Jun. 2008;117(6):449-54. Epub: 2008/03/12. [pmid: 18331577].
48 Kolbasovsky A, Reich L, Meyerkopf N. Reducing six-month inpatient psychiatric recidivism and costs through case management. Care Manag J. 2010;11(1):2-10. Epub: 2010/04/30. [pmid: 20426315].
49 Parson C. Managed care. The effect of case management on state psychiatric clients. J Psychosoc Nurs Ment Health Serv. Oct. 1999;37(10):16-21. Epub: 1999/10/26. [pmid: 10529959].
50 Quinlivan R, Hough R, Crowell A, et al. Service utilization and costs of care for severely mentally ill clients in an intensive case management program. Psychiatr Serv. Apr. 1995;46(4):365-71. Epub: 1995/04/01. [pmid: 7788458].
51 Muijen M, Cooney M, Strathdee G, et al. Community psychiatric nurse teams: intensive support versus generic care. Br J Psychiatry. Aug. 1994;165(2):211-7. Epub: 1994/08/01. [pmid: 7953034].
52 Rothbard AB, Chhatre S, Zubritsky C, et al. Effectiveness of a high end users program for persons with psychiatric disorders. Community Ment Health J. Oct. 2012;48(5):598-603. Epub: 2012/02/01. [pmid: 22290303].
53 Mahendran R, Hendriks M, Thambyrajah V, et al. Case Management in a Psychiatric Hospital: Review of Outcomes and Resource Utilisation. Hong Kong J Psychiatr. 2006;16(1):3-6.
54 Kivlahan DR, Heiman JR, Wright RC, et al. Treatment cost and rehospitalization rate in schizophrenic outpatients with a history of substance abuse. Hosp Community Psychiatry. Jun. 1991;42(6):609-14. Epub: 1991/06/01. [pmid: 1864571].
55 Harrison-Read P, Lucas B, Tyrer P, et al. Heavy users of acute psychiatric beds: randomized controlled trial of enhanced community management in an outer London borough. Psychol Med. Apr. 2002;32(3):403-16. Epub: 2002/05/07. [pmid: 11989986].
56 Preston NJ, Fazio S. Establishing the efficacy and cost effectiveness of community intensive case management of long-term mentally ill: a matched control group study. Aust N Z J Psychiatry. Feb. 2000;34(1):114-21. Epub: 2001/02/24. [pmid: 11185923].
57 Hornstra RK, Bruce-Wolfe V, Sagduyu K, et al. The effect of intensive case management on hospitalization of patients with schizophrenia. Hosp Community Psychiatry. Sep. 1993;44(9):844-7. Epub: 1993/09/01. [pmid: 8225296].
58 Chan S, Mackenzie A, Jacobs P. Cost-effectiveness analysis of case management versus a routine community care organization for patients with chronic schizophrenia (Structured abstract). Arch Psychiatr Nurs. 2000;14(2):98-104. [pmid: 10783528].
59 Husted J, Wentler S, Allen G, et al. The effectiveness of community support programs in rural Minnesota: A ten year longitudinal study. Psychiatr Rehab J. 2000 Sum. 2000;24(1):69-72.
60 Burns T, Creed F, Fahy T, et al. Intensive versus standard case management for severe psychotic illness: a randomised trial. UK 700 Group. Lancet. Jun. 26. 1999;353(9171):2185-9. Epub: 1999/07/07. [pmid: 10392982].
61 Bush CT, Langford MW, Rosen P, et al. Operation outreach: intensive case management for severely psychiatrically disabled adults. Hosp Community Psychiatry. Jun. 1990;41(6):647-9. discussion 9-51. Epub: 1990/06/01. [pmid: 2361668].
62 Schmidt LT, Gill KJ, Pratt CW, et al. Comparison of Service Outcomes of Case Management Teams With and Without a Consumer Provider. Am J Psychiatr Rehab. 2008/10/13. 2008;11(4):310-29.
63 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: part I. Intervention and implementation in a randomized effectiveness trial. Psychiatr Serv. Jul. 2006;57(7):927-36. Epub: 2006/07/04. [pmid: 16816276].
64 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: Part II. Impact on clinical outcome, function, and costs. Psychiatr Serv. Jul. 2006;57(7):937-45. Epub: 2006/07/04. [pmid: 16816277].
65 Bauer MS. The collaborative practice model for bipolar disorder: design and implementation in a multi-site randomized controlled trial. Bipolar Disord. Oct. 2001;3(5):233-44. Epub: 2002/03/21. [pmid: 11903206].
66 Burns T, Rugkasa J, Molodynski A, et al. Community treatment orders for patients with psychosis (OCTET): a randomised controlled trial. Lancet. May. 11. 2013;381(9878):1627-33. Epub: 2013/03/30. [pmid: 23537605].
67 Fernandez GA, Nygard S. Impact of involuntary outpatient commitment on the revolving-door syndrome in North Carolina. Hosp Community Psychiatry. Sep. 1990;41(9):1001-4. Epub: 1990/09/01. [pmid: 2210692].
68 Frank D, Perry JC, Kean D, et al. Effects of compulsory treatment orders on time to hospital readmission. Psychiatr Serv. Jul. 2005;56(7):867-9. Epub: 2005/07/16. [pmid: 16020822].
69 Kisely S, Preston N, Xiao J, et al. An eleven-year evaluation of the effect of community treatment orders on changes in mental health service use. J Psychiatr Res. May. 2013;47(5):650-6. Epub: 2013/02/19. [pmid: 23415453].
70 Nakhost A, Perry JC, Frank D. Assessing the outcome of compulsory treatment orders on management of psychiatric patients at 2 McGill University-associated hospitals. Can J Psychiatry. Jun. 2012;57(6):359-65. Epub: 2012/06/12. [pmid: 22682573].
71 Segal SP, Burgess P. Extended outpatient civil commitment and treatment utilization. Soc Work Health Care. 2006;43(2-3):37-51. Epub: 2006/09/08. [pmid: 16956852].
72 Swartz MS, Swanson JW, Wagner HR, et al. Can involuntary outpatient commitment reduce hospital recidivism?: Findings from a randomized trial with severely mentally ill individuals. Am J Psychiatry. Dec. 1999;156(12):1968-75. Epub: 1999/12/10. [pmid: 10588412].
73 Compton SN, Swanson JW, Wagner HR, et al. Involuntary outpatient commitment and homelessness in persons with severe mental illness. Ment Health Serv Res. Mar. 2003;5(1):27-38. Epub: 2003/02/27. [pmid: 12602644].
74 Vaughan K, McConaghy N, Wolf C, et al. Community treatment orders: relationship to clinical care, medication compliance, behavioural disturbance and readmission. Aust N Z J Psychiatry. Oct. 2000;34(5):801-8. Epub: 2000/10/19. [pmid: 11037366].
75 Hiday VA, Scheid-Cook TL. Outpatient commitment for "revolving door" patients: compliance and treatment. J Nerv Ment Dis. Feb. 1991;179(2):83-8. Epub: 1991/02/01. [pmid: 1990075].
76 Sledge WH, Lawless M, Sells D, et al. Effectiveness of peer support in reducing readmissions of persons with multiple psychiatric hospitalizations. Psychiatr Serv. May. 2011;62(5):541-4. Epub: 2011/05/03. [pmid: 21532082].
77 Pitschel-Walz G, Bauml J, Bender W, et al. Psychoeducation and compliance in the treatment of schizophrenia: results of the Munich Psychosis Information Project Study. J Clin Psychiatry. Mar. 2006;67(3):443-52. Epub: 2006/05/03. [pmid: 16649832].
78 McFarlane WR, Link B, Dushay R, et al. Psychoeducational multiple family groups: four-year relapse outcome in schizophrenia. Fam Process. Jun. 1995;34(2):127-44. Epub: 1995/06/01. [pmid: 7589414].
79 de Groot L, Lloyd C, King R. An evaluation of a family psychoeducation program in community mental health. Psychiatr Rehabil J. Summer. 2003;27(1):18-23. Epub: 2003/09/12. [pmid: 12967228].
80 Prince JD. Practices preventing rehospitalization of individuals with schizophrenia. J Nerv Ment Dis. Jun. 2006;194(6):397-403. Epub: 2006/06/15. [pmid: 16772855].
81 Addington DE, McKenzie E, Wang J. Validity of hospital admission as an outcome measure of services for first-episode psychosis. Psychiatr Serv. Mar. 2012;63(3):280-2. Epub: 2012/01/24. [pmid: 22267251].
82 Mueser KT, Bond GR, Drake RE, et al. Models of community care for severe mental illness: a review of research on case management. Schizophr Bull. 1998;24(1):37-74. [pmid: 9502546].
83 Torrey EF, Zdanowisc MT, Kennard AD, et al. The treatment of persons with mental illness in prisons and jails: a state survey. Arlington, VA. Treatment Advocacy Center and National Sherriff's Association. 2014. www.tacreports.org/treatment-behind-bars. Septermber 7, 2014.
84 Swartz MS, Wilder CM, Swanson JW, et al. Assessing outcomes for consumers in New York's assisted outpatient treatment program. Psychiatr Serv. Oct. 2010;61(10):976-81. Epub: 2010/10/05. [pmid: 20889634].
85 Dummont JM, Jones K. Findings from a consumer/survivor defined alternative to psychiatric hospitalization. Outlook. 2002;(Spring):4-6.
86 Swanson JW, Borum R, Swartz MS, et al. Can involuntary outpatient commitment reduce arrests among persons with severe mental illness?. Criminal Justice and Behavior. Apr 2001. 2001;28(2):156-89.
87 Rohland BM, Rohrer JE, Richards CC. The long-term effect of outpatient commitment on service use. Adm Policy Ment Health. Jul. 2000;27(6):383-94. Epub: 2000/11/15. [pmid: 11077702].
88 Zanni GR, Stavis PF. The effectiveness and ethical justification of psychiatric outpatient commitment. Am J Bioeth. Nov. 2007;7(11):31-41. Epub: 2007/11/21. [pmid: 18027299].
89 Drake RE, McHugo GJ, Clark RE, et al. Assertive community treatment for patients with co-occurring severe mental illness and substance use disorder: a clinical trial. Am J Orthopsychiatry. Apr. 1998;68(2):201-15. Epub: 1998/05/20. [pmid: 9589759].
90 Cuddeback GS, Morrissey JP, Domino ME, et al. Fidelity to recovery-oriented ACT practices and consumer outcomes. Psychiatr Serv. Apr. 1. 2013;64(4):318-23. [pmid: 23318948].
91 Kasprow WJ, Rosenheck RA. Outcomes of critical time intervention case management of homeless veterans after psychiatric hospitalization. Psychiatr Serv. Jul. 2007;58(7):929-35. Epub: 2007/07/03. [pmid: 17602008].
92 Cauchi R, Landess S, Thangasamy A. State Laws Mandating or Regulating Mental Health Benefits. Denver, CO. National Conference of State Legislatures. 2014. January. http://www.ncsl.org/research/health/mental-health-benefits-state-mandates.aspx. 12 Sept.
93 Husted J, Jorgens A. Best practices: Population density as a factor in the rehospitalization of persons with serious and persistent mental illness. Psychiatr Serv. May. 2000;51(5):603-5. [pmid: 10783176].
94 Mancini AD, Moser LL, Whitley R, et al. Assertive community treatment: facilitators and barriers to implementation in routine mental health settings. Psychiatr Serv. Feb. 2009;60(2):189-95. [pmid: 19176412].
95 Rosenberg G, Weissman A, Wong DFK. Clinical Case Management For People With Mental Illness: A Biopsychosocial Vulnerability-Stress Model. 1st ed. London. Routledge. 2014.
96 Sanborn C, editor. Case management in mental health services. New York. Routledge. 1983.
97 Ziguras SJ, Stuart GW. A meta-analysis of the effectiveness of mental health case management over 20 years (Structured abstract). Psychiatr Serv. 2000;51(11):1410-21. [pmid: 11058189].
98 Christy A, Petrila J, McCranie M, et al. Involuntary outpatient commitment in florida: case information and provider experience and opinions. Int J Forensic Ment Health. 2009;8(2):122-30.
99 Miller RD. An update on involuntary civil commitment to outpatient treatment. Hosp Community Psychiatry. Jan. 1992;43(1):79-81. Epub: 1992/01/01. [pmid: 1544658].
100 Geller J, Grudzinskas AJ Jr, McDermeit M, et al. The efficacy of involuntary outpatient treatment in Massachusetts. Adm Policy Ment Health. Jan. 1998;25(3):271-85. Epub: 1998/09/04. [pmid: 9727222].
101 Swartz M, Swanson J, Steadman HJ, et al. New York State Assisted Outpatient Treatment Program Evaluation. Duke University School of Medicine. Durham, NC. 2009. http://www.omh.ny.gov/omhweb/resources/publications/aot_program_evaluation/.
102 Ding R, McCarthy ML, Desmond JS, et al. Characterizing waiting room time, treatment time, and boarding time in the emergency department using quantile regression. Acad Emerg Med. Aug. 2010;17(8):813-23. Epub: 2010/07/31. [pmid: 20670318].
103 Chang G, Weiss A, Kosowsky JM, et al. Characteristics of adult psychiatric patients with stays of 24 hours or more in the emergency department. Psychiatr Serv. Mar. 2012;63(3):283-6. Epub: 2012/01/24. [pmid: 22267250].
104 Fee C, Burstin H, Maselli JH, et al. Association of emergency department length of stay with safety-net status. JAMA. Feb. 1. 2012;307(5):476-82. Epub: 2012/02/03. [pmid: 22298679].
105 Weiss AP, Chang G, Rauch SL, et al. Patient- and practice-related determinants of emergency department length of stay for patients with psychiatric illness. Ann Emerg Med. Aug. 2012;60(2):162-71.e5. Epub: 2012/05/05. [pmid: 22555337].
106 Stephens RJ, White SE, Cudnik M, et al. Factors associated with longer length of stay for mental health emergency department patients. J Emerg Med. Oct. 2014;47(4):412-9. Epub: 2014/07/31. [pmid: 25074781].
107 Lyons JS, O'Mahoney MT, Miller SI, et al. Predicting readmission to the psychiatric hospital in a managed care environment: implications for quality indicators. Am J Psychiatry. Mar. 1997;154(3):337-40. Epub: 1997/03/01. [pmid: 9054780].
108 Kallapiran K, Sankaranarayanan A, Lewin T. A pilot investigation of the relationship between community treatment orders and hospital utilization rates. Australas Psychiatry. Dec. 2010;18(6):503-5. Epub: 2010/12/02. [pmid: 21117836].
109 Program for Evaluating Payment Patterns Electronic Report (PEPPER). This website is developed and maintained by TMF Health Quality Institute, under contract with the Centers for Medicare & Medicaid Services www.pepperresources.org. 08 Sept 2014.
110 Lien L. Are readmission rates influenced by how psychiatric services are organized?. Nord J Psychiatr. 2002;56(1):23-8. [pmid: 6263252].
111 Essock SM, Kontos N. Implementing assertive community treatment teams. Psychiatr Serv. Jul. 1995;46(7):679-83. Epub: 1995/07/01. [pmid: 7552558].
112 Greenberg D, Mazar J, Brom D, et al. Involuntary outpatient commitment: a naturalistic study of its use and a consumer survey at one community mental health center in Israel. Med Law. Mar. 2005;24(1):95-110. Epub: 2005/05/13. [pmid: 15887616].
113 Munetz MR, Grande T, Kleist J, et al. The effectiveness of outpatient civil commitment. Psychiatr Serv. Nov. 1996;47(11):1251-3. Epub: 1996/11/01. [pmid: 8916245].
114 O'Brien AM, Farrell SJ. Community treatment orders: profile of a Canadian experience. Canadian Journal of Psychiatry. Revue Canadienne de Psychiatrie. Jan. 2005;50(1):27-30. Epub: 2005/03/10. [pmid: 15754662].
115 Segal SP, Burgess PM. Conditional release: a less restrictive alternative to hospitalization?. Psychiatr Serv. Nov. 2006;57(11):1600-6. Epub: 2006/11/07. [pmid: 17085608].
116 Rohland BM. The role of outpatient commitment in the management of persons with schizophrenia. Iowa Consortium for Mental Health. Des Moines, IA. 1998.
117 Steadman HJ, Gounis K, Dennis D, et al. Assessing the New York City involuntary outpatient commitment pilot program. Psychiatr Serv. Mar. 2001;52(3):330-6. Epub: 2001/03/10. [pmid: 11239100].
118 Tyrer P, Hassiotis A, Ukoumunne O, et al. Intensive case management for psychotic patients with borderline intelligence. UK 700 Group. Lancet. Sep. 18. 1999;354(9183):999-1000. Epub: 1999/09/29. [pmid: 10501366].
119 Bauml J, Pitschel-Walz G, Volz A, et al. Psychoeducation in schizophrenia: 7-year follow-up concerning rehospitalization and days in hospital in the Munich Psychosis Information Project Study. J Clin Psychiatry. Jun. 2007;68(6):854-61. Epub: 2007/06/27. [pmid: 17592908].
120 Segal SP, Burgess PM. Factors in the selection of patients for conditional release from their first psychiatric hospitalization. Psychiatr Serv. Nov. 2006;57(11):1614-22. Epub: 2006/11/07. [pmid: 17085610].
121 Segal SP, Burgess PM. Use of community treatment orders to prevent psychiatric hospitalization. Aust N Z J Psychiatry. Aug. 2008;42(8):732-9. Epub: 2008/07/16. [pmid: 18622781].
122 Segal SP, Burgess PM. The utility of extended outpatient civil commitment. Int J Law Psychiatry. Nov-Dec. 2006;29(6):525-34. Epub: 2006/10/31. [pmid: 17070577].
123 Elbogen EB, Swanson JW, Swartz MS. Effects of legal mechanisms on perceived coercion and treatment adherence among persons with severe mental illness. J Nerv Ment Dis. Oct. 2003;191(10):629-37. Epub: 2003/10/14. [pmid: 14555864].
124 Maughan D, Molodynski A, Rugkasa J, et al. A systematic review of the effect of community treatment orders on service use (Provisional abstract). Soc Psychiatry Psychiatr Epidemiol. 2014;49(4):651-63. [pmid: 24136002].
125 Kisely S. Randomised controlled evidence for the effectiveness of community treatment orders: An update of a cochrane systematic review. Aust N Z J Psychiatry. 2014;48:110-1. [pmid: 23761575].
126 Rugkåsa J, Dawson J, Burns T. CTOs: what is the state of the evidence?. Soc Psychiatry Psychiatr Epidemiol. 2014;49(12):1861-71. [pmid: 24562319].
127 Burgess P, Bindman J, Leese M, et al. Do community treatment orders for mental illness reduce readmission to hospital? An epidemiological study. Soc Psychiatry Psychiatr Epidemiol. Jul. 2006;41(7):574-9. Epub: 2006/05/11. [pmid: 16685479].
128 Busch AB, Wilder CM, Van Dorn RA, et al. Changes in guideline-recommended medication possession after implementing Kendra's law in New York. Psychiatr Serv. Oct. 2010;61(10):1000-5. Epub: 2010/10/05. [pmid: 20889638].
129 Van Dorn RA, Swanson JW, Swartz MS, et al. Continuing medication and hospitalization outcomes after assisted outpatient treatment in New York. Psychiatr Serv. Oct. 2010;61(10):982-7. Epub: 2010/10/05. [pmid: 20889635].
130 Kisely S, Campbell LA, Preston NJ, et al. Can epidemiological studies assist in the evaluation of community treatment orders? - The experience of Western Australia and Nova Scotia. Int J Law Psychiatry. Nov-Dec. 2006;29(6):507-15. Epub: 2006/10/28. [pmid: 17067675].
131 Hunt AM, da Silva A, Lurie S, et al. Community treatment orders in Toronto: the emerging data. Can J Psychiatry. Oct. 2007;52(10):647-56. Epub: 2007/11/21. [pmid: 18020112].
132 Segal SP, Preston N, Kisely S, et al. Conditional release in Western Australia: effect on hospital length of stay. Psychiatr Serv. Jan. 2009;60(1):94-9. Epub: 2008/12/31. [pmid: 19114577].
133 Muirhead D, Harvey C, Ingram G. Effectiveness of community treatment orders for treatment of schizophrenia with oral or depot antipsychotic medication: clinical outcomes. Aust N Z J Psychiatry. Jun-Jul. 2006;40(6-7):596-605. Epub: 2006/06/08. [pmid: 16756586].
134 O'Brien AM, Farrell SJ, Faulkner S. Community treatment orders: beyond hospital utilization rates examining the association of community treatment orders with community engagement and supportive housing. Community Ment Health J. Dec. 2009;45(6):415-9. Epub: 2009/09/04. [pmid: 19728089].
135 Preston NJ, Kisely S, Xiao J. Assessing the outcome of compulsory psychiatric treatment in the community: epidemiological study in Western Australia. BMJ. May. 25. 2002;324(7348):1244. Epub: 2002/05/25. [pmid: 12028977].
136 Churchill R, Owen G, Singh S, et al. International experiences of using community treatment orders. London, England. 2007.
137 Kisely S, Campbell LA, Scott A, et al. Randomized and non-randomized evidence for the effect of compulsory community and involuntary out-patient treatment on health service use: systematic review and meta-analysis (Structured abstract). Psychol Med. 2007;37(1):3-14. [pmid: 16923325].
138 Swartz MS, Burns BJ, George LK, et al. The ethical challenges of a randomized controlled trial of involuntary outpatient commitment. J Ment Health Adm. Winter. 1997;24(1):35-43. Epub: 1997/01/01. [pmid: 9033154].
139 Gold PB, Meisler N, Santos AB, et al. The Program of Assertive Community Treatment: Implementation and dissemination of an evidence-based model of community-based care for persons with severe and persistent mental illness. Cog Behav Pract. 2003;10:290-303.
140 Watanabe-Galloway S, Watkins K, Ryan S, et al. Adult general psychiatric patients served in Nebraska's state hospitals: patient characteristics and needs. Community Ment Health J. 2014. Apr. 2. Epub: 2014/04/03. [pmid: 24691573].