# Next Steps

Based on the literature review and interviews with Key Informants, we identified certain questions that need to be explored to identify the most effective management strategies to reduce psychiatric hospital readmissions.

Several studies address this topic, and the bulk of them address two interventions: intensive case management, which has a variety of definitions, and Assertive Community Treatment (ACT), which has more clearly defined standard of care. These strategies are not mutually exclusive, and they can involve overlapping components. Determining the most effective strategy requires knowing which components or packages of components are most effective in improving outcomes, and how to deliver an effective outcome in a given location (which can have variability in available resources). Addressing this issue entails several important next steps.

## 1 Determine the Key Components, or Packages of Components, That Are Most Effective To Keep Those at High Risk of Psychiatric Hospitalization Functioning in the Community as Much as Possible

Our review identified a substantial amount of literature focusing on complex interventions. However, outside of ACT, we did not identify an overall theoretical model that identified what components may be important and why, nor did our review of the literature provide an empirical basis for identifying what components may be most effective. To address this issue, a first step would be the development of a theoretical model that attempts to identify the key components from the available literature, followed by primary data collection to test the most effective combination of these components. Prospectively collected data would allow the most careful comparative testing of these components, which might include randomized controlled trial or prospective cohort studies. The subsequent study would need to be able to clearly define the population at risk, operationalize an intervention that can be applied in a variety of settings, include an informative control group, measure meaningful outcomes, and implement the intervention with fidelity over a time frame that can allow one to see meaningful change. An important consideration here is determining the effectiveness of these strategies outside of psychotic disorders and bipolar disorder. Nearly all of the evidence addressing the use of these strategies in those at risk of rehospitalization involves these diagnoses; the effectiveness of these strategies in other populations that may receive this intervention (major depressive disorder, posttraumatic stress disorder, personality disorders) is less well understood.

## 2 Determine How To Accurately Measure the Most Meaningful Outcomes

Accurate collection of outcome data has been problematic for this area of study; the reliability and validity of psychiatric readmission data are uncertain because datasets may not be comprehensive, a limitation that may bias an effect negatively or positively. Consequently, having high-quality data that can comprehensively capture the relevant outcomes is key. Further, the number of psychiatric readmissions or the psychiatric readmission rates may not be the most important outcomes to study; indeed, in some cases, psychiatric readmission can be the correct outcome. More relevant ones may include other measures such as length of hospital stay, engagement while outside of hospital, and functioning in the community, each of which has been assessed in prior studies. A conference that involves relevant stakeholders, including patients, families, clinicians, researchers, payers (county, State, federal) and funders, could determine which appear to be the most meaningful outcomes to study and where they might fit into a theoretical model of how the interventions should work. Prospective trials could then include these measures.

## 3 Determine How To Most Efficiently Apply Effective Strategies to Areas With Varying Resources

Variability in resources, especially problematic for a chronically ill, resource-intensive population, can substantially affect successful implementation of effective interventions. Cost and resource availability may be key barriers. Dissemination and implementation research could help identify the most effective means of implementing evidence-based strategies in settings with variable resources, with important foci on economically feasible and sustainable interventions.