# Key Informants

(*also provided review of the draft report)

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Dan Bradford, M.D., M.P.H.
  Veterans Administration
  Durham, NC
- *David Chambers, D. Phil.
  National Institute of Mental Health
  Bethesda, MD
- Benjamin Druss, M.D., M.P.H.
  Emory University
  Atlanta, GA
- *Laura Fochtmann, M.D., M.B.I.
  Stony Brook University School of Medicine
  Stony Brook, NY
- *Paul Gionfriddo
  Mental Health America
  Alexandria, VA
- *Karen E. Johnson, M.S.W.
  Universal Health Services
  King of Prussia, PA
- Amy Kilbourne, Ph.D., M.P.H.
  VA Quality Enhancement Research Initiative (QUERI) and the University of Michigan Health System
  Ann Arbor, MI
- *Kathleen McCann, R.N., Ph.D.
  National Association of Psychiatric Health Systems
  Washington, DC
- *Steven S. Sharfstein, M.D.
  Sheppard Pratt Health System
  Baltimore, MD