# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Kim Wittenberg, M.A. We thank our Associate Editor, Mary Butler, Ph.D., for her helpful comments on a draft version of the report.

The authors deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at the RTI–UNC EPC. We express our gratitude to the following individuals for their contributions to this project: Loraine Monroe, Sharon Barrell, M.A., and Erin Boland, B.A., of RTI, and Halle Amick, M.S.P.H., and Christiane Voisin, M.L.S., of UNC.