# Findings

For each of the following sections, we will first provide a summary of the key findings and then provide a detailed synthesis of the data collected.

## Discussion of Interventions: Core Components for Management Strategies (GQ 1)

### Key Findings

This section describes categorizations, advantages and disadvantages, variation in use, and harms of four management strategies: length of stay (LOS), transition support services, short-term alternatives to psychiatric rehospitalization, and long-term approaches for reducing psychiatric rehospitalization. In contrast to LOS in a psychiatric hospital, which is a distinct approach to reducing readmissions without any component parts, the other three strategies involve various components that can overlap at times (e.g., case management services could be a part of either a transition support service or a long-term approach for reducing readmissions). We have conceptualized transition support services as services following hospital discharge, short-term alternatives to psychiatric rehospitalization as relatively short-term services (i.e., lasting weeks to months) targeting patients at high risk of readmission who may be in crisis but are not an imminent danger to self or others, and long-term approaches (i.e., lasting months to years) for reducing psychiatric rehospitalization in this group. We acknowledge that at times these strategies may overlap.

Other than Assertive Community Treatment (ACT), we did not identify an overall theoretical model that identified what components may be important and why, nor did our review provide an empirical basis for identifying what components may be most effective. We found several studies reflecting on the reasons for success or failure of novel applications of various management strategies, but comparatively few on variations in use and harms. The latter data require sustained evaluation of implementation and dissemination efforts, for which we found no studies. Also, we found one y comparing the advantages and disadvantages of different management strategies.

#### Categorizations of Management Strategies (GQ 1)

Length of stay for psychiatric hospitalizations. Literature regarding LOS and psychiatric readmissions is limited, and there is a lack of consistency regarding what constitutes brief, average, and long LOS.19,20 LOS categorizations in the literature cover longer lengths of time than those mentioned by KIs. One study categorized LOS into less than 30 days, versus 31 days and longer;20 a second study used less than or equal to 1 week as well as 8 to 14 days (brief stay); 15 to 30 days (average stay); 31 to 60 days (longer than average stay); more than 60 days (extended stay).19 Both of these studies are from the early- to mid-1990s; what is considered brief, very brief, or long has probably changed considerably. KIs offered somewhat different interpretations of LOS: less than 4 days (brief stay); 4 to 14 days (intermediate stay); more than 14 days (long stay). A short-stay category of 24 hours may be referred to as observation status.

Transition support services for psychiatric hospitalization discharges. Table 2 describes the various types of transition support services included in the literature: aftercare services, a computerized decision-support tool for coordination of inpatient and outpatient services, supervised discharge, needs-oriented discharge planning, and transitional discharge services. Although the literature describes the provision of transition support services, no consensus exists regarding optimal alternatives to psychiatric rehospitalization.

Table 2 Overview of types of transition support services

Type of Transition Support Service | Description
Aftercare services | Services include weekly followup calls, home visits, and psychoeducation services for family members of the patient21,22 or individualized transitional psychoeducation and long-term preventive monitoring.23
Computerized decision-support tool for coordination of inpatient and outpatient services | Computerized decision-support tool for psychiatrists to enhance coordination of services by providing suggestions for services. These services are based on certain clinical and psychopathological conditions of the patient, including psychoeducation, group therapy, and social-worker care, which would then be provided by the local hospital. The software makes these recommendations when clinical or psychopathological needs are met.24
Needs-oriented discharge planning | Needs assessment to standardize discharge planning, outpatient treatment, and adherence. Adherence to this plan is then monitored during the postdischarge period.25,26
Supervised discharge | Supervised discharge refers to specifying a location of treatment or residence for patients upon discharge, and may include several features, such as requiring attendance at specific treatment sessions and allowing access to a community supervisor.27,28
Transitional discharge services | This model includes two parts: (1) peer support for a period of 1 year, and (2) ongoing support provided by hospital staff to form a therapeutic relationship with the community care provider.29 In the peer-support phase, peer volunteers help patients form friendships, and teach them skills useful for transition to the community. Activities in this phase of the therapeutic drug monitoring included telephone conversations and meeting for coffee.

##### Short-Term Alternatives to Psychiatric Rehospitalization

Table 3 describes the two types of short-term alternatives to rehospitalization included in the literature. Crisis residential care is a treatment modality that is available outside an individual’s home in the case of psychiatric destabilization not requiring involuntary commitment. It exists in many forms but is meant to be less restrictive and less expensive than regular inpatient psychiatric care, and thus an alternative. It is also intended primarily for individuals voluntarily seeking treatment without significant comorbid medical needs that would necessitate an inpatient level of care.30-32 Scheduled intermittent hospitalizations are planned short-term psychiatric inpatient admissions for persons with serious mental illness ranging from 3 to 11 days every 3 months.32,33

Table 3 Overview of types of short-term alternatives to rehospitalization

Type of Alternative to Rehospitalization | Description and List of Relevant Studies
Crisis residential care | Crisis residential care is a mechanism to provide an intermediate level of care between standard outpatient treatment and involuntary psychiatric hospitalization to conserve resources and promote the least restrictive environment, with goals that include proactively decreasing the need for inpatient days.30-32
Scheduled intermittent hospitalization | Planned short-term psychiatric inpatient admissions for persons with serious mental illness ranging from 3 to 11 days every 3 months.32,33

Long-term approaches for reducing psychiatric rehospitalization. Our literature search revealed four main categories of long-term approaches for reducing psychiatric rehospitalization: (1) ACT, (2) involuntary outpatient commitment (OPC) or compulsory treatment orders (CTOs), (3) case management (intensive or nonintensive), (4) collaborative care, (5) peer support, (6) psychoeducation, and (7) various outpatient services. Table 4 lists each long-term approach for reducing psychiatric rehospitalization, along with brief descriptions of each.

Table 4 Overview of types of long-term approaches for reducing psychiatric rehospitalization

Type of Long-term Approach for Reducing Rehospitalization | Description and List of Relevant Studies
Assertive Community Treatment | ACT is a form of multidisciplinary, wraparound outpatient care that is available 24/7 and targeted at individuals with severe and persistent mental illness to support placement in the community instead of extended inpatient psychiatric care (historically in State hospitals).34-45
Case management | Support services, usually provided by a case manager, nurse, or other health care professional, provided to the patient based on assessment of the patient’s needs to ensure needs are met.46-61 In some cases, case management services may also be provided by a consumer provider.62 When being considered a specific strategy, one is usually referring to intensive case management.
Collaborative care | A collaborative care model to treat chronic bipolar disorder among veterans treated at Veterans Affairs hospitals was created by identifying important patient characteristics, sources of provider variability, and system-related barriers and then combining and modifying two different conceptual models to best meet patient needs given their available resources.63-65
Involuntary outpatient commitment or compulsory treatment orders | Involuntary OPC, existing in the United States, and CTOs, existing abroad, are legal orders that compel individuals with mental illness to engage in outpatient treatment to avoid future rehospitalization.66-75
Peer support | Peers (former mental health patients in recovery) who receive a salary for their services, but do not report back to the mental health system, provide support and mentorship to their mentees.76
Psychoeducation | Psychoeducation services, such as sessions provided by therapists where patients (and possibly to their relatives) are taught about stressors, etc. during inpatient stays.77-79
Various outpatient services | Services include (1) day treatment or partial hospitalization, (2) intensive psychiatric rehabilitation, (3) vocational services, (4) prevocational services, and (5) detoxification services. These services addressed various issues such as (1) medication education, (2) symptom education, (3) care continuity, (4) social relations, (5) daily structure, (6) daily living, and (7) kin involvement.80

ACT = Assertive Community Treatment; CTO = compulsory treatment order; OPC = involuntary outpatient commitment.

ACT is an evidence-based practice for the treatment of individuals with severe and persistent mental illness and recent history of repeat psychiatric hospitalizations, criminal justice involvement, homelessness, and/or comorbid substance use.81 The model is based on a multidisciplinary team composed of social workers, rehabilitation therapists, nurses, and a psychiatrist with a low client-to-staff ratio (1:10), frequent visits in the community, 24/7 availability, and the ability to provide comprehensive services, as well as assertive community outreach for individuals requiring assistance in engaging in treatment.45 It is meant to provide highly individualized wraparound services so that a client does not have to work with multiple providers and can be supported through most psychiatric crises without hospitalization, and thus provide care in the least restrictive environment.44 Originally pioneered in the late 1970s in Madison, Wisconsin, ACT was developed as part of a “quest for alternatives to mental hospital treatment for patients that suffer from chronically disabling psychiatric illness.”37 Subsequently, modified forms (with larger caseloads and decreased visit frequency) have been created to fit local funding and personnel constraints, particularly in developing countries.36

An OPC (as it exists in the United States) or CTO (as it exists in the United Kingdom, Canada, New Zealand, Australia, and Israel) is a form of compulsory outpatient psychiatric treatment that involves some degree of legal enforcement, with large variations based on jurisdiction and specific State/country law. For example, outpatient commitment laws in the United States require a judge’s order, supported by clinician input, and generally do not allow patients to be given medications forcibly. Compulsory treatment orders, also referred to as community treatment orders, can often be implemented by a clinician, without the need for court involvement, and in some countries, such as Australia and Canada, the administration of intramuscular forced medication is allowed as part of the order. The concept of compulsory outpatient treatment developed from numerous forces, including deinstitutionalization of those individuals with a serious mental illness beginning in the 1950s, rising hospital readmissions, and public concern arising from rare, but tragically violent acts committed by individuals with serious mental illness living in the community, who were often found to be nonadherent to treatment.66,70,72 OPC/CTO requires individuals to engage in psychiatric treatment in the community for a certain period of time or be faced with returning to the hospital for treatment and involves input from clinicians and the judicial system. The literature implies that some individuals may need involuntary treatment to prevent readmission because of the high prevalence of anosognosia (i.e., lack of insight as part of the disease process) with severe and persistent mental illness.71,72 Specifics of the orders (e.g., whether medication can be given forcibly by intramuscular injection and what conditions need to be met to actually return a patient to an inpatient setting involuntarily) vary by specific State and country. However, all are based on the principle that compelling outpatient treatment will avoid future hospitalizations, and thus, be less restrictive overall.73

Several studies examined case management, including intensive case management (ICM), and its use as a transition support service. Nonintensive case management includes many of the same components as ICM, such as ongoing assessment of the patient needs, monitoring progress, defining outcomes of care, and linking patients with supportive resources.47 Although there is general agreement that ICM more aggressively and proactively maintains contact with patients, and attempts have been made to conceptualize case management models that can vary by intensity,82 the literature shows that the difference between intensive and nonintensive case management has been difficult to articulate,60 and we found no clear guideline, standard, or fidelity scale for case management. A retrospective cohort study that examined how case management teams staffed with consumer providers differed from those staffed with professionally trained nonconsumer providers, with respect to service delivery and outcomes, found that teams with consumer providers with significant life experience but limited educational background were likely to have outcomes comparable with teams led by nonconsumer staff.62

Various psychoeducation services are described in the literature, including group therapy sessions provided to patients and their relatives.77 One study focused in particular on comparing single family psychoeducational treatment (where a minimum of three sessions for family engagement was followed by two or three educational sessions to educate family members on various aspects of disease and management, concluding with sessions with a clinician who helped implement guidelines) with multiple-family psychoeducational treatment (where five families were assigned to each group and then received an educational workshop).78

We found a single study that examined peer support, in which a recovering mental health patient provided support and mentorship to a current patient.76 KIs identified this intervention as an important strategy whose use was increasing.

Collaborative care is a general term, but there is literature describing a specific model of collaborative care for bipolar disorder aimed at reducing psychiatric hospitalization.63-65 This particular program incorporated all of the domains of a chronic medical care model: patient self-management, provider decision support, delivery system redesign, and facilitation of information flow (e.g., scheduled and unscheduled care, telephone contacts, missed appointments, liaison to other providers, hospitalizations, and information flow).65

KIs also raised the alternatives described above during interviews. In addition, they noted that jails and prisons have become a significant, albeit unintended, alternative to psychiatric hospitalization. Data support this observation. Approximately 20 percent of jail inmates and 15 percent of State prisoners have a serious mental illness, a rate that is approximately 10 times that of individuals with serious mental illness remaining in State hospitals.83

##### Advantages/Disadvantages

We found several studies reflecting on the reasons for success or failure of all three management strategies. A number of studies focused on novel implementation of transition support services, short-term alternatives to psychiatric rehospitalization, and long-term approaches for reducing psychiatric rehospitalization in particular (Table 5). One study compared the advantages or disadvantages of different management strategies.84 We present the results below as potential or theoretical advantages or disadvantages rather than as empirical evidence of comparative advantages or disadvantages.

Table 5 Advantages and disadvantages of management strategies

| Length of Stay for Psychiatric Hospitalizations | Transition Support Services for Psychiatric Hospitalization Discharges | Short-Term Alternatives to Psychiatric Rehospitalization | Long-Term Approaches for Reducing Psychiatric Rehospitalization
Advantages | - Brief LOS: deinstitutionalization and freeing up of hospital beds to accommodate more patients who require inpatient treatment; - Longer LOS: additional monitoring that patients receive, and the opportunity to be stabilized via treatment | - Computerized decision-support tool: provides recommendations for interventions to reduce readmissions; - Supervised discharge: NR; - Needs-oriented discharge planning and peer-support services: NR | - Crisis residential care: maintenance of continuity with community supports, greater levels of healing, empowerment and satisfaction, shorter LOS, and cost savings; - Scheduled intermittent hospitalization: NR | - ACT: decreased hospital admissions or bed days, increased social functioning and consumer satisfaction, sustained contact with difficult-to-engage patients; - Collaborative care: fewer hospitalizations; - ICM: adaptable, potential to lower costs associated with hospital readmissions; - Nonintensive case management programs: NR; - OPC/CTO: fewer hospitalizations, decreased homelessness, reduced seclusion and restraint, possible synergistic effect when combined with long-acting injectable antipsychotics, decreased arrest for subgroups, increased engagement in community treatment; - OPC/CTO combined with ACT: fewer hospitalizations than ACT alone, increased engagement in outpatient services; - OPC/CTO combined with ICM: fewer hospitalizations than ACT alone, increased engagement in outpatient services; - Psychoeducational services: may satisfy information needs and relieve emotional stress of patients and families
Disadvantages | - Brief LOS: difficulty in clearly identifying patients who require longer care; - Longer LOS: unintended consequences of hospitalization (e.g., infections) | - Computerized decision-support tool: lack of adaptability or utility for patients with wide range of needs or high rates of readmissions; - Needs-oriented discharge planning NR; - Supervised discharge: potentially negative perception | - Crisis residential care: NR; - Scheduled intermittent hospitalization: NR | - ACT: Services focused on medication education: unique contribution of service unclear: varying data about its cost-effectiveness, labor intensive compared with other forms of case management; - OPC/CTO: unclear or inconsistent information on optimal length of commitment and outcomes following expiration of court order; - Case management in general: more expensive than usual care, result in heavier workloads for case managers, potentially poorer results; - ICM: professional staff may initially resist the use of community-living aides to support them; - Collaborative care: NR; - Peer-support services: NR; - Psychoeducational services: may require consistent use of services, may not be effective without trained staff and clinicians with dedicated time; - Services focused on medication education: unique contribution of service unclear; - ACT: varying data about its cost-effectiveness, labor intensive compared with other forms of case management

ACT = Assertive Community Treatment; CTO = compulsory treatment order; ICM = intensive care management; LOS = length of stay; NR = not reported; OPC = involuntary outpatient commitment.

Length of stay for psychiatric hospitalizations. Potential advantages of brief LOS include deinstitutionalization and freeing up of hospital beds to accommodate more patients who require inpatient treatment.19,20 However, a potential disadvantage in brief LOS is the difficulty in clearly identifying patients who require longer care.19 KIs pointed out that the primary advantages of longer stays are the additional monitoring that patients receive, and the opportunity to be stabilized via treatment. They noted that among the disadvantages of longer stays are unintended consequences of hospitalization (e.g., acquiring infections, loss of job, loss of housing). Also, the lack of knowledge regarding the specific consequences of longer hospitalizations (e.g., beyond 20 days) is a disadvantage for a provider who needs to make a decision about the LOS.

Transition support services for psychiatric hospitalization discharges. The literature regarding advantages and disadvantages associated with each type of transition support service summarized in Table 5 is limited, particularly for certain interventions.

Aftercare services have the advantage of being low-intensity services, particularly when compared with Assertive Community Treatment or intensive case management, which could increase costs or limit access when continued for prolonged periods of time.22 Additionally, aftercare services may appeal to patients with a wide range of mental illnesses.23 A potential disadvantage of aftercare services is the challenge associated with establishing these in low- or middle-income countries.21

A computerized decision-support tool has the advantage of providing recommendations for interventions to reduce readmissions, but its primary disadvantage is the tool’s lack of adaptability to meet the needs of patients with a wide range of needs. In particular, the authors point to the tool’s inability to provide the level of care and support needed by patients who have high rates of readmissions.24 These patients did not participate in the intervention or quit the intervention early.24

The literature is lacking regarding advantages of supervised discharge. One disadvantage is concern about how it may be perceived. When it was introduced in the 1990s, supervised discharge was seen to be ineffective and was not viewed positively in the mental health community.27 It is unclear from the available information whether this perception has changed.

The literature is lacking regarding advantages and disadvantages of needs-oriented discharge planning and peer-support services.

One potential disadvantage, raised by a study of the transitional discharge model, is the potential for under-implementation in health systems. For this particular intervention, under-implementation may have been driven by part-time hours, lack of therapeutic relationship, sickness, very few day shifts, and resistance to changing individual and hospital system practice.29

Short-term alternatives to psychiatric rehospitalization. Given the small number of articles meeting inclusion criteria that addressed crisis residential care or scheduled intermittent hospitalizations, we found little discussion about advantages and disadvantages beyond the examination of the primary outcome of reduction in hospitalization. We did find data supporting cost-effectiveness of residential crisis programs and scheduled hospitalizations.31-33,85 Other possible advantages mentioned included enhanced continuity with community supports, greater client satisfaction/self-esteem, and decreased complaints of negative emotions and physical symptoms.31,33,85

Long-term approaches for reducing psychiatric rehospitalization. The literature did not mention any specific advantages of ACT in comparison with other long-term approaches for reducing psychiatric hospitalization, nor did the KIs delineate any. However, the primary advantages of ACT as a treatment modality include its consistent ability to decrease hospital admissions or bed days,34,44,45 even in modified forms;36 its ability to sustain contact with difficult-to-engage patients (such as clients requiring home-based services due to lack of insight or other psychological factors);38,43 and its ability to affect other outcomes such as increased social functioning and consumer satisfaction.34,45 A major disadvantage mentioned in the literature is varying data about its cost-effectiveness45 and that it is labor intensive compared with other forms of case management.41

The literature identified by this Technical Brief minimally addressed advantages and disadvantages of OPC/CTO outside of the primary outcome of a reduction in hospitalization, and KIs did not offer additional comments or comparisons with other alternatives to rehospitalization. One study was able to demonstrate that involuntary outpatient commitment decreased homelessness during the 4-month period following hospital discharge for participants with severe functional impairment at baseline.73 Another study reported that patients with extended OPC/CTO and a prior history of multiple hospitalizations and prior arrests/violent behavior (≥180 days) had a lower probability of arrest than before OPC/CTO.86 In yet another study, patients receiving OPC/CTO and long-acting injectables demonstrated a higher adherence rate and lower readmission rate than patients receiving OPC/CTO and oral medications.74 Because the comparison group did not experience the same effect, the authors suggested that OPC/CTO may be particularly advantageous when combined with long-acting injectable medications.74 Additionally, two included studies identified increased engagement in community treatment during the course of the order as a positive, albeit predictable, outcome of OPC/CTO.84,87 Finally, one study suggested that OPC/CTO was associated with decreased episodes of seclusion and restraint in addition to decreased episodes of hospitalization.88 Although not strictly a disadvantage, a limitation of OPC/CTO implied by the literature is that the optimum length of commitment to ensure desired outcomes remains unclear given that studies were inconsistent on whether extended periods of commitment were necessary to demonstrate a reduction in hospital utilization (whether by readmission or LOS)67-69,72 and whether treatment maintenance continued after the court order expired.70,75

Potential advantages of ICM include its role in reducing costs associated with hospital readmissions and its ability to be easily adapted to various contexts.46,50 Disadvantages may include additional new costs being incurred for the mental health systems to run ICM; we found conflicting information on whether this disadvantage may be minimized by significant reductions in inpatient costs, although the findings lean toward ICM being cost effective.50,54-56 As noted by a KI, the complexity of considering the advantages and disadvantages is notable in the following scenario: ICM could produce overall cost savings by getting people care earlier in a severe episode, which could cause a paradoxical increase in readmissions but allows symptoms to be controlled more rapidly and hence could lead to shorter stays and fewer total hospital days. Professional staff may initially resist the use of community-living aides (who serve as peer-support specialists) as part of ICM.50 However, in one instance, these concerns were alleviated by competent community-living aides who were able to demonstrate their value to professional staff.50 We found very limited information in the literature on the advantages of nonintensive case management programs. One of the major disadvantages of case management in general is that these interventions rely heavily on the case managers and their workloads, and heavy workloads may contribute to disappointing results.47 Additionally, case management is more expensive than providing usual care.58

Only one study compared different management strategies with one another, specifically, the combination of ACT and OPC/CTO with the combination of ICM and OPC/CTO and with ACT alone.84 Aside from the interventions’ effects on hospitalization, patients receiving either combined intervention were more engaged in outpatient services as rated by case managers than patients receiving ACT alone. No information about the comparative disadvantages of these interventions was available.

A potential advantage of psychoeducational services is that these interventions satisfy the information needs and relieve the emotional stress of patients and their families.77 A study on multifamily groups noted that the tone of these groups tends to be more upbeat and positive than in single family groups.78 Another advantage of multifamily groups is more productive problem-solving as a result of group functioning with more people with the same problem working toward a solution.78 A potential disadvantage associated with psychoeducational services is that the benefit accrued from these services is directly related to whether patients (and their relatives, if applicable) make use of the services in a consistent manner.77 Psychoeducational services, when offered in real-world settings, may not be as effective as research studies with trained staff and clinicians with dedicated time to meet with participants in the psychoeducational services as frequently as required.79

Only one study addressed collaborative care and contained little discussion about advantages and disadvantages beyond the examination of the primary outcome of reduction in hospitalization. The KIs did not address collaborative care.

A single study comparing various outpatient services noted that the disadvantages of services focused on medication education included the fact that most patients have already learned about their medications from their hospitals, and information about medication use is easily available even without the service. The study did not comment on the advantages or disadvantages of other services such as symptom education, service continuity, and daily structure.80

##### Variation in Use by Patient Demographics, Diagnosis, and Coexisting Conditions

In general, we found very little information on variations in use for transition support services: the little specific information we found relates to intensive case management. We found no studies on LOS or transition support services; information continues to be lacking on specific issues as variation in use by coexisting conditions (Table 6).

Table 6 Variation in use of management strategies

| Length of Stay for Psychiatric Hospitalizations | Transition Support Services for Psychiatric Hospitalization Discharges | Short-Term Alternatives to Psychiatric Rehospitalization | Long-Term Approaches for Reducing Psychiatric Rehospitalization
Variations in use by patient demographics | - Low SES and accompanying severity of illness and instability of residence may result in multiple short stays or longer LOS per stay | - NR | - NR | - ACT: wide implementation, likely not affected by patient demographics.; - OPC: use varies by State laws within the U.S.; - Collaborative care model: NR
Variations in use by patient diagnosis | - First episodes of schizophrenia and patients hospitalized with “other psychosis diagnosis” likely to have longer LOS; - Substantial variation in LOS for patients with personality disorders | - NR | - NR | - ACT: designed for individuals with serious mental illness who are relatively heavy inpatient service utilizers; - OPC/CTO: also designed for patients with serious mental illness (e.g., primary psychotic disorders); - Collaborative care model: one study in bipolar patients
Variations in use by patient coexisting conditions | - Longer LOS for patients with co-occurring substance abuse who need rehabilitation services and pose safety concerns; - Shorter LOS likely for dual-diagnosis patients if providers believe that they will continue their substance use regardless of care received as inpatients | - Schizophrenia patients with a history of substance abuse had more psychiatric hospitalizations during the first year of the community support program with intensive case management than patients without substance abuse histories. | - NR | - NR

ACT = Assertive Community Treatment; CTO = compulsory treatment order; LOS = length of stay; NR = not reported; OPC = involuntary outpatient commitment; SES = socioeconomic status.

Length of stay for psychiatric hospitalizations. Information is lacking in the literature on whether LOS varies by patient demographics, diagnoses, and coexisting conditions. However, KIs commented extensively on these issues. They pointed out that patients with the lowest socioeconomic status, including the poor, uninsured, and the homeless, have shorter LOS and are more likely to have multiple short stays. However, some KIs also noted that Medicaid patients sometimes have paradoxically longer LOS than patients with private insurance for a variety of reasons, among them not having a stable home to be discharged to and the severity of their illness.

With respect to diagnoses, KIs noted that patients with first episodes of schizophrenia have longer LOS, as do patients admitted with the ICD-9 code corresponding to “unspecified psychosis.” The latter category often corresponds to patients for whom treatment is complex and challenging, therefore leading to longer LOS. KIs indicated that LOS can vary substantially among patients with personality disorders because these patients may use language to prompt a hospital admission and can lead hospitals into either extending or shortening their stays. Preparing a treatment plan that is safe from a medical and legal standpoint for patients with personality disorders may be especially difficult when they have a chronic history of suicide attempts or self-harm.

KIs identified substance abuse as a comorbidity that is strongly related to LOS. For dual-diagnosis patients, LOS tends to have two very different potential patterns: some patients who are judged to need substance abuse rehabilitation services because of safety concerns may have a longer LOS in the psychiatric hospital during the transfer process whereas some dual-diagnosis patients may also be discharged quickly because health care providers believe that they will continue their substance use regardless of care received as inpatients.

Transition support services for psychiatric hospitalization discharges. We found no data regarding how transition support services vary by patient demographics, diagnosis, and coexisting conditions.

Short-term alternatives to psychiatric rehospitalization. The included literature did not comment on variation in use of any of the short-term alternatives to psychiatric rehospitalization by patient demographics, diagnosis, and coexisting conditions.30-32 Because only one collaborative care model was identified, and it was specifically designed for individuals with bipolar disorder,63-65 variation in use of this alternative to rehospitalization is essentially unknown.

Long-term approaches for reducing psychiatric rehospitalization. ACT has been applied in a multitude of settings, both rural and urban, and across a diverse set of countries, suggesting that it is not affected by patient demographics.34-36,40,44,45 High-fidelity ACT clearly specifies components and processes89,90 and, if administered correctly, should not vary substantially. The original investigators designed ACT for adults with serious mental illness (who may use resources heavily and be hospitalized repeatedly), rather than for other diagnostic groups. The populations involved were composed primarily of patients with schizophrenia, schizoaffective disorder, and bipolar disorder, although comorbid substance abuse was common. It has also been used with other diagnostic groups that are relatively heavy inpatient service utilizers, such as those with chronic depression,43,44,59 borderline personality disorder,32,51,70,79 and posttraumatic stress disorder,32,49,91 although the evidence base and use in these groups is less substantial.

OPC/CTO was generally designed to target individuals with serious mental illness (as opposed to the general psychiatric population) and, accordingly, is most frequently used for patients with primary psychotic disorders. This approach is supported by data that OPC/CTOs may be most effective for individuals with nonaffective psychoses72 and/or individuals without insight or with severe functional impairment.67 Most States within the United States have OPC laws, although the laws may differ among States, and States may variably apply the law; as a result, use of OPC varies based on geography.72

In one study, schizophrenia patients with a recent or lifetime history of substance abuse had more psychiatric hospitalizations while they were enrolled in the first year of a community support program with intensive case management than did patients without a history of substance abuse.54 However, differences in outpatient Medicaid charges were not statistically significant.54 Other data on how transition support services vary by patient demographics, diagnosis, and other factors are lacking.

The KIs did not offer any additional insights into how any of the discussed long-term approaches to reducing rehospitalization vary by demographics, diagnosis, and/or coexisting conditions.

##### Harms

In general, we found limited information on harms (Table 7) but note that potential or theoretical disadvantages of a particular approach, when disseminated and implemented widely, could result in harms.

Table 7 Harms of management strategies

Harm | Length of Stay for Psychiatric Hospitalizations | Transition Support Services for Psychiatric Hospitalization Discharges | Short-Term Alternatives to Rehospitalization | Long-Term Approaches for Reducing Psychiatric Rehospitalization
Unintended consequences | Infections associated with longer LOS | NR | NR | NR
Early discharge not addressing treatment needs | Shorter LOS (or early discharges based on resolution of safety issue upon admission) do not address the need for sufficient longer-term treatment | NR | NR | Prioritizing the least restrictive environment conflicts with benefits from longer hospital stays
Early discharge into poorly developed community health system | Shorter LOS can be disastrous in contrast to those discharged to a well-developed community health system | NR | NR | NR
Forcing treatment | NR | NR | NR | Potential ethical concerns if the ends are not thought to justify the means.

LOS = length of stay; NR = not reported.

Length of stay for psychiatric hospitalizations. The information in the literature regarding harms is lacking, but KIs discussed the possibility of unintended consequences, such as infections, of longer LOS. KIs noted that in many cases, patients are discharged from psychiatric hospitals as soon as the safety issue prompting admission is stabilized, without providing sufficient longer-term treatment. KIs also pointed out that the implications of different LOS depend on available community resources. For instance, a shorter LOS can be very effective within a well-developed community mental health system but disastrous if used within a poorly developed one.

Transition support services for psychiatric hospitalization discharges. We found no data from the literature regarding harms and safety concerns associated with these transition support services.

Short-term alternatives to psychiatric rehospitalization. We found no data from the literature regarding harms and safety concerns associated with short-term alternatives to psychiatric rehospitalizations.

Long-term approaches for reducing psychiatric rehospitalization. The literature identified for inclusion in the Technical Brief was largely silent on the issue of potential patient harms or safety concerns related to each of the identified long-term approaches for reducing psychiatric rehospitalization. The OPC/CTO literature noted the challenge of balancing restrictions on individual liberty with the potential benefits of longer treatment. In this regard, if this equipoise is not achieved, one could theoretically, albeit unintentionally, do harm. In addition, one study questioned whether those with serious mental illness might benefit from longer hospital stays and criticized the premise of prioritizing the least restrictive environment.69 KIs seconded this concern.

### Discussion of Interventions: Description of the Context for Using Management Strategies (GQ 2)

#### Key Findings

This section describes contextual issues associated with the use of management strategies, specifically variation in these strategies, outcomes measured by studies of management strategies, and resources required to ensure their optimal use.

Variations in practice, in summary, concern differences in State and local policies; resources such as beds; payment systems and financial incentives; infrastructure; and definition, application, and implementation of management strategies.

Regarding outcomes measured by studies of management strategies, evidence suggests that the most commonly measured outcome, psychiatric readmissions, is likely to undercount true readmission rates. In addition to concerns about the reliability and validity of this outcome, studies and KIs note the value of measuring other indicators of well-being, such as psychiatric symptomatology, functional status, quality of life, social adjustment, self-efficacy, service satisfaction, life skills, medication adherence, and ability to live independently, and process measures, such as continuity of outpatient care, housing stability, and employment. In essence, readmissions may be a small piece of the puzzle, and other measures of well-being and functioning need to be measured.

No identified studies directly tested the effect of training, certification, staffing, and resources to improve management strategies used to prevent psychiatric readmission. Several studies, however, implicated deficiencies in training, staffing, or resources as a factor in the failure of management strategies.

#### Variation in Management Strategies Across the United States

##### Current Management Strategies

Management strategies to reduce psychiatric readmissions vary across the United States. Few published studies detail and compare strategies across geographic locations. Nonetheless, information from individual States or regions or factors known to influence strategies that may differ by location can begin to shed light on these differences. State and local policies that influence payment mechanisms and the impact of a community’s mental health infrastructure on access to care may lead to varying ways of managing adults with frequent psychiatric hospitalizations.41 For example, some State parity laws cover all people with mental illness, whereas others require that the disorder have a biological basis or be classified as a serious mental illness for coverage eligibility.92 One study found differences in rehospitalization rates by urban-rural setting,93 which may suggest the need for different strategies based on surrounding location.

The literature describes some variation in the availability of effective ACT. A high-fidelity ACT team has well-defined components, and several validated scales can be used to measure such fidelity: originally the Dartmouth Assertive Community Treatment Scale89 and, more recently, the Tool for the Measurement of Assertive Community Treatment,90 which adds emphasis to the inclusion of recovery-oriented practices. Given the highly prescribed components and processes of an ACT team, there should be little variation in implementation or practice despite varying locales. However, the availability of high-fidelity ACT varies greatly across the United States and internationally, and outcomes can vary based on the fidelity of the team.94

Variation in other types of case management results from the constantly evolving definition and applications of mental health case management services.95-97 Although most case management definitions include the notion of a collaborative, coordinated process of helping a person with mental illness receive high-quality services in a cost-effective manner, the process of doing so is not uniform across programs. Some case managers may help with the assessment, planning, facilitation, and/or advocacy of needed services; others also become involved with the monitoring and evaluation of the care received. Other variations stem from differences in following practice standards; use of an individual or team approach; and levels of frequency, intensity, and duration of the case management services. The range of services overseen by a case manager may include medical, social, educational, vocational, and other services as needed by each individual patient.

KIs discussed several ways that strategies vary across the United States and factors to explain this variation. Some variation may be due to payment strategies that may encourage new ways to help people avoid psychiatric hospitalization. For example, financial incentives to keep people out of the hospital are greater in areas where prospective payment systems are in place, and hospitals are paid on a per-case, per-episode basis. In contrast, less financial incentive exists in areas where hospitals are reimbursed based on volume (i.e., by each day patients stay in the hospital, even with utilization review).

In addition to payment strategies, KIs discussed an example of a State policy influencing strategies currently used. Texas’s State-run mental health system strongly resembles the 190-day lifetime approach to managing hospital readmissions, which requires discharged patients to remain out of the hospital for a certain amount of time before they can be readmitted. KIs acknowledged that the success of this approach depends greatly on individual States’ regulation and the interest of the legislature in addressing the issue of repeated psychiatric hospitalizations.

A majority of States have addressed this issue with OPC or assisted outpatient treatment programs.98,99 The goal of these programs is to ensure that individuals with mental illness with a history of repeated hospitalizations participate in community-based mental health services with the ultimate objective of keeping them out of inpatient settings. States with these programs vary in program design and implementation.98 In Iowa, the State code allows a person who had been committed to inpatient treatment to be transferred to OPC upon written petition documenting the absence of being “gravely disabled.” Compliance with a set schedule of followup treatment visits determines whether the patient can remain out of the hospital.87 Massachusetts has a similar involuntary outpatient treatment procedure with distinct eligibility criteria and treatment plan ordered by the court.100 These programs improve adherence with outpatient treatment87 and have been shown to lead to significantly fewer emergency commitments,98 hospital admissions,87 and hospital days100 as well as a reduction in arrests and violent behavior.86,101 Finally, KIs acknowledged that unintentional alternatives to hospitalization such as extended emergency department (ED) stays might be used when psychiatric beds are not available. Several prior studies have shown that the LOS for psychiatric patients is prolonged because of the lack of available psychiatric beds as well as payment-related factors.102-106 After a patient has spent several days in the ED, a physician might deem the patient ready for discharge, even when the patient is likely to still be experiencing extended distress. These situations have received national attention and sparked political debate, particularly when the discharged patient commits a highly violent act.

##### Recent Developments in Management Strategies

KIs noted several new developments in management strategies. Strategies with a self-monitoring component have been increasingly used and tested, especially with the increasing proliferation of new information technologies. Many of these strategies are being delivered over the Internet using technology such as Skype and other types of self-reporting strategies to increase the role of self-monitoring and improve connectedness with providers. National Institute of Mental Health research also is evaluating interventions that use the ideas of self-monitoring and potential passive sensing of functional status, as well as warm handoffs of care to identify acute crisis States. These ideas are still in development, rather than in current use but are likely to be implemented if found to be effective.

#### Outcomes Measured by Management Strategy Studies

##### Reliability and Validity of Psychiatric Readmissions Data

The reliability and validity of psychiatric readmission data are questionable.81,107 Although we found no published literature addressing this issue directly, many studies discuss study design and data limitations such as small sample sizes, short followup periods, and the absence of a comparison group.108 Use of administrative data to examine readmissions is subject to several caveats. The KIs noted that the accuracy of administrative data systems tracking hospital admissions varies by region. Sometimes data on readmissions are limited to a single unit, facility, organization, State, or insurer. For example, the KIs noted that even when the Medicare Program for Evaluating Payment Patterns Electronic Report program109 accurately captures readmissions data for Medicare beneficiaries, individual hospitals currently do not have a means of determining when patients they have discharged are readmitted to a different hospital. One KI’s hospital’s psychiatric ED tracks where patients are referred following discharge; the number of patients who are readmitted to the same hospital represents a very small proportion of readmissions.

Even if all readmissions can be identified, rates may appear lower than they are because people may experience other undetectable adverse events such as incarceration or death. Some patients also may experience an extended ED stay rather than a readmission when beds are not available. The use of administrative data to study psychiatric rehospitalizations, however, provides the benefit of examining many different variables for a large number of people at a lower cost than randomized controlled trials (RCTs). KIs noted that the National Institute of Mental Health has been investing in a project that is formally called the Mental Health Research Network, which uses large datasets to answer questions such as what the frequency and correlates of repeated psychiatric readmissions are.

One related issue involves how the data are analyzed. For example, data on readmissions and ED visits are likely to be skewed. Thus, using statistics such as means may not accurately represent the extent of the problem. This is particularly true when a small part of the population in the “skewed” region uses a disproportionate amount of resources. In this case, a management strategy may be determined effective because it helped the many less severe patients but not the more complex patients, or it greatly helped the few more complex patients but not the less severe patients at all. Knowing the effectiveness for both of these groups could help tailor the strategies to those mostly likely to benefit.

##### Other Key Outcomes to Consider (e.g., Successful Return to Community, Suicide, Incarceration)

An analysis of the comparative effectiveness of management strategies to reduce readmissions should consider outcomes other than readmissions. Management strategies to reduce readmissions may influence indicators of well-being such as psychiatric symptomatology, functional status, quality of life, social adjustment, self-efficacy, service satisfaction, life skills, medication adherence, and ability to live independently.41 These strategies also may decrease the risk of adverse outcomes like incarceration or death (including suicide), and may reduce various types of health care utilization, such as ED visits (nonpsychiatric), rehospitalizations, and outpatient visits.29,41,69,74,79

KIs stressed the importance of also studying process measures that affect ultimate outcomes. For example, they suggested examining continuity of outpatient care and specific indicators of functioning such as housing stability and employment, as well as the presence of a supportive environment. Although readmission is seen as an adverse outcome, the number of days of successful living in the community and the length of stay of readmissions provide context for readmission data.110 Failing to examine these measures may lead to false conclusions that a management strategy had no positive influences on outcomes.

#### Training, Certification, Staffing, and Other Resources Required to Ensure Optimal Use of These Management Strategies

Several resources may help ensure optimal use of management strategies. Although no identified studies directly tested the effect of training, certification, staffing, and resources to improve on management strategies used to prevent psychiatric readmission, several studies suggest that inadequate training may be responsible for at least part of a particular strategy’s ineffectiveness29 and that enhanced knowledge through training may improve outcomes.53

One study points to the benefits of coordinated care from a team of providers, including case managers, physicians, nurses, social workers, and occupational therapists with shared caseloads, low staff-to-client ratios, time-unlimited services, and 24-hour availability of staffing, as well as the use of electronic medical records to improve outcomes.35 Another study determined that including a consumer provider who is recovering or has recovered from a mental illness (i.e., peer support) can add additional empathy and insight to a case management team and yield similar outcomes when compared with case management teams without such providers.62

For labor-intensive strategies, constraints on these resources can affect their successful implementation. For example, as noted earlier, the availability of high-fidelity ACT can vary greatly across the United States and internationally, which can limit the feasibility of its effective implementation94 and raise questions about its sustainability if those resources become further constrained.

Greater efficiencies in outpatient care and community services also may place less strain on the mental health care system and ultimately optimize inpatient care. For example, having community supports, such as day centers or partial hospitalization and outpatient services, assessments from an occupational therapist, coordination of medication management, and assurance of high levels of patient contact after discharge, are important.36 In addition, other improvements crucial to optimizing care include enhancing the efficiencies of the outpatient and community services systems themselves by reducing the administrative burden on case managers in applying for insurance or supported housing for those in need, providing incentives for treating patients with more complex needs rather than rejecting the more serious patients, and reducing gaps in treatment or medication adherence because of insurers requiring preauthorization for care or few participating providers accepting new treatments.

### Evidence Map: Current Evidence about the Effectiveness of These Management Strategies (GQ 3)

We identified 64 studies reported in 78 publications that assessed the link between a management strategy and readmission in those at risk of readmission to a psychiatric unit. Two studies involved LOS approaches,19,20 five (seven articles) studies assessed the use of transition support services,21,23-26,28 four studies (five publications) addressed short-term alternatives to psychiatric rehospitalization,30-33,85 and 53 considered long-term approaches for reducing psychiatric rehospitalization.28,34-36,38-53,55-62,64,66,67,69-72,74,76-80,84,88,98,100,108,111-117 in 64 publications21,23,25,27,28,34-36,38-53,55-67,69-74,76-80,84,86,88,98,100,108,111-123 We include a summary of potentially relevant ongoing and unpublished studies in Appendix D.

We identified three systematic reviews evaluating the effectiveness of OPC/CTO for reducing psychiatric hospital readmissions in those at high risk of psychiatric readmission.124-126 The reviews synthesized information from individual studies our literature review had already captured,66,69,70,72,84,88,98,115,117,120,121,127-137 Their findings are consistent with what we reported for included studies.

In the sections below, we first provide a general overview of the Evidence Map for each strategy, then a summary of key findings, and finally a detailed description of the current evidence addressing the effectiveness of each management strategy. For the detailed description, we first review the study design of the available research and then address key points of each study’s population, intervention(s), comparator(s), and outcomes (PICOs). For the outcomes, we identify the studies’ consideration of our primary outcomes (LOS, number of readmissions, and readmission rate) and report which secondary outcomes are measured. Because a Technical Brief does not evaluate study findings, including assessing risk of bias and strength of evidence, we do not report statistical significance in our findings. Instead, if a study’s outcome was statistically significant, we report the finding without statistical language (e.g., the intervention decreased the number of readmissions). If study authors report a finding that they identify as near statistical significance, we describe a trend. If the study authors describe an outcome that suggests an effect but do not statistically test, we describe the appearance of an effect. If the study authors analytically test for an effect and find no difference, we report the finding of no difference. Tables that provide a detailed breakdown by PICOs are provided in Appendix E.

#### Overview of Evidence Map

The evidence map in Table 8 graphically represents the universe of available studies that address the three primary readmission outcomes in GQ 3. The evidence base includes RCTs, cohort studies, single group pre-post studies, and case-control studies; we highlight those with RCT evidence in our discussion of key findings. LOS studies are substantially limited in number, while case management studies and ACT have the greatest number of studies available, many of which are RCTs.

Table 8 Evidence map of management strategies

Management Strategy | Intervention Subtype | Number of Readmission(s) | Readmission Rate | Length of Stay of Readmission(s)
Length of stay | Shorter stays | 1 cohort | 1 cohort
Transition support services | Aftercare services | 2 RCTs | 1 RCT | 1 RCT
Transition support services | Decision-support tool | 1 cohort | 1 cohort | 1 cohort
Transition support services | Supervised discharge | 1 single group pre-post | | 1 single group pre-post
Transition support services | Needs-oriented discharge | | 1 RCT | 1 RCT
Short-term alternatives to psychiatric rehospitalization | Crisis residential care | 1 RCT | 1 RCT 1 case-control | 1 RCT
Short-term alternatives to psychiatric rehospitalization | Scheduled intermittent hospitalization | 1 RCT 1 single group pre-post | 1 single group pre-post | 1 RCT 1 single group pre-post
Long-term approaches for reducing psychiatric rehospitalization | ACT | 4 RCTs 2 cohort 1 single group pre-post | 2 RCTs 3 cohort 2 single group pre-post | 5 RCTs 2 cohort 4 single group pre-post
Long-term approaches for reducing psychiatric rehospitalization | Case management | 5 RCTs 3 cohort 1 single group pre-post | 2 RCTs 4 cohort 1 single group pre-post | 7 RCTs 5 cohort 2 single group pre-post
Long-term approaches for reducing psychiatric rehospitalization | Collaborative care | | 1 RCT
Long-term approaches for reducing psychiatric rehospitalization | OPC/CTO | 2 RCTs 3 cohort 10 single group pre-post | 2 RCTs 2 cohort 3 single group pre-post | 3 RCTs 2 cohort 2 case-control 8 single group pre-post
Long-term approaches for reducing psychiatric rehospitalization | Peer support | 1 RCT | | 1 RCT
Long-term approaches for reducing psychiatric rehospitalization | Psychoeducation | 1 RCT 1 cohort | 2 RCTs | 1 RCT 1 cohort
Long-term approaches for reducing psychiatric rehospitalization | Various outpatient services | | 1 cohort

ACT = Assertive Community Treatment; CTO = compulsory treatment order; OPC = involuntary outpatient commitment; RCT = randomized controlled trial.

Table 9 lists the secondary outcomes reported in the eligible articles addressing management strategies. The specific outcomes listed indicate those that we had identified a priori as the most important secondary outcomes for patients, providers, family members, and policymakers. The “other” column includes additional outcomes reported in studies that are of likely interest to stakeholders. Although a variety of patient-centered outcomes are commonly reported in these studies, very few provide any data on adverse events.

Table 9 Secondary outcomes reported in management strategy studies

Management Strategy | Intervention Subtype | Total Number of Studies | Studies Reporting Adherence/ Engagement^a^ | Studies Reporting Mental Health^b^ | Studies Reporting Satisfaction^c^ | Studies Reporting Quality of Life^d^ | Studies Reporting Adverse Events | Studies Reporting Cost and Resource Utilization^e^ | Studies Reporting Other Outcomes^f^
Length of stay | Shorter stays | 2 | None | None | None | None | None | None | None
Transition support services | Aftercare services | 2 | 1 | 1 | 1 | 1 | 1 | None | 1
Transition support services | Decision support tool | 1 | 1 | None | 1 | 1 | None | 1 | None
Transition support services | Needs-oriented discharge | 1 | 1 | 1 | None | 1 | None | None | 1
Transition support services | Supervised discharge | 1 | None | None | None | None | None | None | None
Short-term alternatives to psychiatric rehospitalization | Crisis residential care | 2 | None | 2 | 2 | 2 | 1 | 2 | 1
Short-term alternatives to psychiatric rehospitalization | Scheduled intermittent hospitalization | 2 | 1 | 1 | 1 | None | None | 1 | 1
Long-term approaches for reducing psychiatric rehospitalization | ACT | 12 | 4 | 4 | 3 | 5 | 1 | 7 | 4
Long-term approaches for reducing psychiatric rehospitalization | Collaborative care | 1 | None | 1 | 1 | 1 | None | 1 | None
Long-term approaches for reducing psychiatric rehospitalization | OPC/CTO | 18 | 8 | 4 | 1 | 4 | 1 | 5 | 7
Long-term approaches for reducing psychiatric rehospitalization | Case management | 16 | 8 | 4 | 4 | 6 | None | 10 | 5
Long-term approaches for reducing psychiatric rehospitalization | Peer support | 1 | 1 | None | None | None | None | None | None
Long-term approaches for reducing psychiatric rehospitalization | Psychoeducation | 3 | 1 | 1 | 1 | 1 | None | None | None
Long-term approaches for reducing psychiatric rehospitalization | Various outpatient services | 1 | None | None | None | None | None | None | None

a Treatment adherence, Clinical engagement (outpatient contacts, continuity, intensity).

b Psychiatric symptom scores; Suicide, suicide attempts, other self-injurious behaviors; Homicide and other aggressive behaviors.

c Satisfaction with care, Individual and family feelings about adequately addressing factors prompting the admission, Individual and family felt the stay was sufficient to address safety and dangerousness concerns.

d Social and occupational functioning, other psychosocial scores, GAF, etc.

e Cost, ED visits for psychiatric reasons.

f Housing stability, social support, physical health outcomes, relapse into substance abuse, criminal justice encounters, mortality, personal care or self-care skills, community living skills, number of met and unmet needs, treatment failure rates, successful return to community, day hospital attendance, sheltered workshop attendance, combined rates of inpatient treatment and criminal justice encounters, referrals to other health services providers, side effects from antipsychotic medication usage.

ACT = Assertive Community Treatment; CTO = compulsory treatment order; ED = emergency department; GAF = Global Assessment of Functioning scale; OPC = involuntary outpatient commitment.

#### Key Findings

##### Length of Stay

We found no RCTs, but two retrospective cohort studies addressed this strategy.19,20

##### Transition Support Services

We also found a small evidence base on transition support services. Studies generally support the provision of such services, but we found little consensus on the optimal approach. Also, we found that categories of transition support strategies might not be discrete; rather, they might make up an array of overlapping and interdependent components which, themselves, may overlap with short-term alternatives to psychiatric rehospitalization or long-term approaches for reducing psychiatric rehospitalization used for high-risk individuals. Furthermore, few studies address advantages, disadvantages, and harms of these strategies.

Two RCTs of aftercare services found that aftercare and psychoeducation led to a lower number of readmissions when compared with usual care in one study21 and a lower average rate of compulsory readmission than those receiving treatment as usual in the other trial.23 A single RCT of needs-oriented discharge planning reported in two articles25,26 indicated no difference in either readmission rates or LOS.

##### Short-Term Alternatives to Psychiatric Rehospitalization

For crisis residential care, one RCT (reported in two articles)30,31 indicated no clear benefit for residential crisis care in comparison with admission to a psychiatric hospital. Alternative-treated patients did not differ in readmissions but did experience longer average LOS when readmitted. A single RCT of planned intermittent hospitalization reported no difference in the number of readmissions or the length of stay.33

##### Long-Term Approaches for Reducing Psychiatric Rehospitalization

Long-term approaches for reducing psychiatric rehospitalization have a moderate evidence base that most consistently supports the use of one strategy: ACT. Again, we found limited information on the advantages, disadvantages, and variations in use as a function of demographics, diagnosis, and coexisting conditions. Six of the seven long-term approaches for reducing psychiatric rehospitalization had RCT data.

Of the 12 ACT studies we identified, 5 were RCTs. Results were inconsistent but generally supported ACT. Three studies36,38,40 found a reduction in the number of readmissions, and one43 did not. Readmission rates decreased in 2 studies,36,38 although these improvements may be seen with patients in State hospital settings rather than in private psychiatric hospitals.38 Reductions in the LOS were greater for ACT patients than those in control groups in 4 of the studies36,38,40,111 and not different in one.43

Of the 18 studies assessing OPC/CTO interventions, 3 had RCT data. No difference was found in any of the primary outcomes,66,72,117 but in subsequent repeated measures analyses examining the role of outpatient treatment specifically among psychotically disordered individuals, results indicated that sustained outpatient commitment reduced hospital readmissions when combined with a higher intensity of outpatient treatment.72 This finding suggests a role for the interdependence of the various strategies, and it hints that the benefit of OPC/CTO may be attributed to the intensity of service rather than the coerciveness of the intervention.

Case management has been the most studied (16 studies, 7 of which are RCTs).46-53,55-62 Six of the 7 RCTs showed no difference in the number of hospital readmissions or patients readmitted; one showed a decrease in the number of readmissions.61 RCT evidence provided inconsistent data for decreasing the length of hospital stays (2 showing decrease50,58 and 4 showing no difference47,51,55,60).

For collaborative care, a single RCT (reported in three articles63-65) reported a trend toward decreased readmission rates following the second and third years of implementation.

Peer support studies consisted of one single RCT76 reporting fewer readmissions and decreased LOS for the peer mentor group in comparison with usual care.

Finally, the psychoeducation evidence base included two RCTs (reported in three studies). Two RCTs indicated that psychoeducation produced lower rates of readmission,78,119 while one RCT reported that psychoeducation produced fewer readmissions and decreased LOS.78,119

In addition to the primary readmission outcomes measured, studies measured a large variety of secondary outcomes that reflected important, patient-centered outcomes, including quality of life, patient engagement, patient satisfaction, clinical engagement, legal involvement, treatment adherence, and health services use and cost (Table 8).

#### Current Detailed Evidence for Length-of-Stay Interventions

Data addressing LOS in this population was very limited (see Appendix E, Table E-1). In the two studies addressing this strategy,19,20 the populations consisted solely of patients with psychotic illness who were assessed for periods of at least 12 months. No consistent LOS category was used; one compared a longer hospital-stay unit (mean LOS, 69 days) with short-stay units (mean LOS, 32 to 35 days),20 and the other compared increasing LOS with a stay of 1 week or less.19 Outcomes studied included number of readmissions20 and readmission rates.19 Both studies used retrospective cohort designs. Results indicated that the number of readmissions did not vary by LOS,20 but the readmission rate was greater in patients with shorter hospital stays.19,20

#### Current Detailed Evidence for Transition Support Services

Information on transition support services are provided in Tables E-2. In this section, we review the literature addressing each strategy in more detail.

##### Aftercare Services

Two RCTs evaluated the combination of psychoeducation and monitoring after discharge (Table E-2). Planning for services began in the hospital just prior to discharge to interface with subsequent outpatient care. One trial focused on psychoeducation for family members and aftercare services (telephone followup and home visits) compared with usual care.21 Aftercare services led to a lower number of readmissions at 1 year compared with usual care. Secondary outcomes focused on measures of mental health, satisfaction, and quality of life. The second trial involved individualized psychoeducation and long-term preventive monitoring compared with usual care.23 Patients receiving the psychoeducation and long-term preventive monitoring intervention had a lower average rate of compulsory readmission than those receiving treatment as usual. Secondary outcomes included clinical engagement and adherence, adverse events, unemployment risk, and duration of illness.23

##### Computerized Decision Support Tool for Coordination of Inpatient and Outpatient Services

One nonrandomized controlled study compared a complex computerized decision support tool with treatment as usual in a population with psychotic disorders over a 12-month followup period (Table E-2).24 Outcomes included number of readmissions, readmission rates, and LOS. Secondary outcomes included adherence with treatment, satisfaction with care, global assessment of functioning, and cost and health services utilization. The study used a matched control group. Readmission appears to have been assessed by self-report except in cases of absence or withdrawal from treatment, in which case it was abstracted from hospital files. The number of readmissions, the readmission rate, and the LOS were all decreased in the intervention group.

##### Supervised Discharge

One single group pre-post design study (two articles)27,28 involving only 22 patients compared supervised discharge with unsupervised discharge (Table E-2). Approximately 90 percent of the patients had a psychotic disorder and 10 percent a mood disorder, and followup was 3 years. Outcomes included number of readmissions and LOS. After supervised discharge, patients appeared to have a decreased number of readmissions and LOS.

##### Needs-Oriented Discharge Planning

One RCT (two articles)25,26 compared a needs-oriented discharge planning and monitoring strategy with treatment as usual over an 18-month period (Table E-2). Approximately 60 percent of the patients had a psychotic disorder, and 40 percent a mood disorder. Outcomes included readmission rates and LOS. Secondary outcomes included adherence, clinical engagement, global assessment of functioning, mental health outcomes (e.g., psychiatric symptom scores), and quality of life measures. The study found no differences between the two groups on readmission rates and LOS.

#### Current Detailed Evidence for Short-Term Alternatives to Psychiatric Rehospitalization

##### Crisis Residential Care

One RCT (two articles30,31) compared a community residential alternative with a psychiatric admission (Table E-3). Approximately half had a psychotic disorder, and the remainder had a mood or personality disorder. Outcomes included readmission rate and LOS. Secondary outcomes included measures of mental health, patient satisfaction, quality of life, cost and health services use, and criminal justice encounters. During the 6-month post-treatment period, the readmission rate for alternative-treated patients did not differ from those who were hospitalized at baseline. Further, alternative-treated patients experienced significantly longer average LOS when readmitted than the hospitalized group.

A 12-month case-control study examined whether access to residential care service plus usual services was better than usual service alone in patients with a DSM-III-R diagnosis and found it reduced readmission rates (Table E-3).85 Secondary outcomes included measures of mental health, patient satisfaction, quality of life, adverse events, and cost and health services use.

##### Scheduled Intermittent Hospitalization

A single small RCT compared planned intermittent hospitalization with unplanned emergency hospitalizations or standard care and reported that the number of readmissions decreased within the planned hospitalization group, but no difference was seen with LOS (Table E-3).33 Subjects were primarily psychotic, mood, and anxiety disorder patients with comorbid polysubstance use disorders. Secondary outcomes included measures of adherence to planned readmissions, psychiatric symptoms, physical symptoms, quality of life, self-esteem, substance abuse, and community adjustment.

One pre-post analysis assessed the effect of planned hospital admissions for a Veterans Administration patient population (Table E-3).32 One-quarter had a psychotic disorder, one-fifth had a mood disorder, and the remainder had posttraumatic stress disorder. Outcomes included number of hospitalizations, number of unplanned hospitalizations, and average LOS and involved the 44 patients remaining from the 81 originally enrolled. Following this program, the total number of hospitalizations increased, but there was a substantial decline in the number of unplanned hospitalizations, the average LOS per hospitalization, and the cost per patient. Secondary outcomes included measures of cost.

#### Current Detailed Evidence for Long-Term Approaches for Reducing Psychiatric Rehospitalization

Information on long-term approaches for reducing psychiatric rehospitalization are provided in Tables E-4 (ACT studies), E-5 (OPC/CTO studies), E‐6 (case management), E-7 (psychoeducation), and E-8 (collaborative care, peer support, and various other services).

##### Assertive Community Treatment

Twelve studies assessed the effectiveness of ACT in reducing psychiatric readmissions34-36,38-45,111 (Table E-4). Five studies were RCTs,36,38,40,43,111 three studies were cohort studies,35,39,42 three were pre-post comparisons of the same group,34,44,45 and one was a secondary analysis of study data comparing different ACT programs.41 Again, in all cases, the population was either entirely or predominantly patients with primary psychotic disorders.

For RCTs, comparators included usual care36,40,43,111 or a drop-in center supplemented by aftercare services.38 Outcomes included number of readmissions,36,38,40,43 readmission rates,36,38 and lengths of stay.36,38,40,43,111 Secondary outcomes included measures of clinical engagement,38,111 mental health (e.g., psychiatric symptom scores),36,38,43 quality of life,36,38,43 satisfaction with care,38,43 health services utilization,38 housing stability,38,43,111 and criminal justice encounters.40 Results indicated decreased readmission rates with ACT interventions36,38 but suggested this improvement may be seen with patients in State hospital settings rather than private psychiatric hospitals.38 For the remaining primary outcomes, results were inconsistent. Reductions in the number of readmissions were greater for ACT patients than control group patients in three of the four studies with that outcome measure,36,38,40 and LOS was reduced in four of the five studies measuring that outcome.36,38,40,111 In each case, there was no difference for those outcomes in the other study that measured them.43

Cohort studies provided inconsistent results. Comparators included usual care35,42 and individual ICM (to contrast with the group approach used by ACT teams).39 Outcomes included readmission rates,35,39,42 number of readmissions,35 and LOS.35,39,42 Secondary outcomes included clinical engagement,35 mental health measures,42 quality of life measures,42 and health services measures.35,39 Results were mixed. Findings from one study indicated that readmission rates in the ACT group had a greater decrease than the control group35 but not in the other,42 and that group case management used with ACT produced more consistent results than individual ICM.39 The number of readmissions decreased more in the ACT group35 and did so more consistently than in ICM.39 One study suggested a greater decrease in LOS with ACT,35 whereas two did not.39,42

Pre-post comparisons suggested benefit for ACT. Outcomes included readmission rates and lengths of stay.34,44,45 Secondary outcomes included quality of life measures34 and cost and health services utilization measures.34,44,45 All three studies showed reductions in the primary outcomes.

The secondary data analysis compared seven ACT programs that varied in intensity of service, and it suggested that higher intensity services produced more robust outcomes.41 Secondary outcomes included satisfaction with care. The data indicated no significant differences between services and change in hospital use among the different ACT programs. In a secondary analysis, four programs with moderate or substantial impact in reducing hospital days also had moderate to high levels of service intensity. Three programs with minimal impact on hospital use had moderate to low service intensities.

##### Involuntary Outpatient Commitment and Compulsory Treatment Orders

OPC, as it is known in the United States, and CTO, as it is known in the United Kingdom, Canada, New Zealand, and Australia, are based on the principle that people with severe mental disorders who are at risk of becoming dangerous or gravely disabled without treatment and reluctant or unable to follow through with community-based treatment, can be required to engage in outpatient treatment as the less restrictive long-term approach for reducing inpatient rehospitalization.

Eighteen studies assessed its effectiveness (Table E-5): 10 were labeled as an OPC67,72,84,88,98,100,112,113,116,117 and 8 (in 11 articles) were labeled CTOs.66,69-71,74,108,114,115,120-122 Of the 18 studies, 3 were RCTs,66,72,117 3 (reported in 6 articles) were a retrospective cohort design,74,84,114,115,120-122 3 were a case control design,69,71,100 and 9 were pre-post testing of the same group.67,70,88,98,108,112-114,116 In all cases, the population was predominantly patients with psychotic disorders; the remainder were patients with mood disorders or to a small degree, other diagnosis types, such as personality disorder, organic mental disorder, or patients with Axis II traits. Intensity of the OPC and CTOs varied from 30 days to 10 years.

For the three RCTs, the comparators were a rehabilitation practice used during a period of involuntary hospital treatment,66 those who were released from OPC,72 or an enhanced service package.117 Outcomes included readmission rate,66,72,117 number of readmissions,72 and LOS.66,72,117 Secondary outcomes assessed quality of life;66,117 incidence of homelessness;73 mental health;66,117 health services measures;66 and other outcomes, such as arrests, treatment nonadherence, and perceived level of coercion.117 No difference was found in any of the primary outcomes.66,72,117 However, in subsequent repeated measures analyses examining the role of outpatient treatment among psychotically disordered individuals, results indicated that sustained OPC reduced hospital readmissions when combined with a higher intensity of outpatient treatment.72

Four retrospective cohorts (in seven articles)74,84,100,115,120-122 examined readmissions. Only one looked at hospital days.100 One employed a matched control group as a comparator.74 Outcomes included readmission rates. Secondary outcomes measures included clinical engagement,74,84,120,122 disturbed behaviors,74 medications prescribed,74 and medications. CTO was not beneficial given that more CTO patients were readmitted than the matched cohort without CTO.74 One study was a large retrospective cohort analysis of about 25,000 patients over a 10-year period that compared those on required CTO as a requirement for conditional release with those not on CTO.115,120-122 CTO patients had more readmissions but had a decrease in the average LOS. CTOs initiated in the community had shorter LOS compared with those initiated in the hospital or those initiated in both settings.121 Patients with extended CTOs (i.e., ≥180 days) had fewer readmissions and shorter LOS than those on extended (i.e., ≥180 days) voluntary outpatient treatment.122 Another study compared OPC in combination with intensive case management or ACT to ACT alone and reported a decrease in readmission rates.84 A separate analysis within this study found that both short- and long-term OPC led to reduced readmission rates and hospital bed-days compared with the pre-OPC period.84 The fourth study reported significantly fewer admissions and hospital days after court order.100

Two case-control studies used control groups as comparators.69,71 Outcomes included LOSs.69,71 Secondary outcome measures included clinical engagement,71 quality of life,69 and cost and health services utilization measures.69,71 For those with CTOs, both studies showed reductions in LOS,69,71

For the nine pre-post design studies, outcomes included number of readmissions,67,88,98,108,112-114,116 readmission rates,70,88,114 and LOS or hospital days.67,88,108,112-114,116 Secondary outcomes included clinical engagement and adherence,87,113,114 mental health,87 patient satisfaction,112 quality of life,113 cost and resource utilization,113 housing status,113,114 comorbid substance abuse,113 criminal justice encounters,113 seclusion episodes and hours when readmitted,88 restraint episodes and hours when readmitted,88 number of patients appealing their CTOs,112,114 number of CTOs reissued,114 patient awareness of their rights under OPC,112 and patients’ and therapists’ views of OPC’s impact on the therapeutic relationship.112 After being placed under an OPC, patients experienced reductions in numbers of readmissions,67,98,108,112-114,116 readmission rates,70,114 and LOS.67,108,112,113,114,116

##### Case Management

Case management, especially ICM in some form has been the most studied approach: 16 (in 17 articles) studies have assessed its effectiveness46-53,55-62,118 (Table E-6). What distinguishes intensive case management from case management often is not clearly defined in studies. In this section, we categorize an intervention as ICM if the authors refer to it using that term or if the authors describe a specific program that provides an intensity of service beyond standard case management (in which the case manager's primary role is limited to connecting the patient to needed services and to coordinating between different service providers).82 Appreciating the varying interpretation of what constitutes ICM, we also list in Table E-6 any specific name a strategy was given.

Seven of the studies were RCTs,47,50,51,55,58,60,61 seven were cohort studies of varying designs,46,48,49,52,56,57,62 and two were pre-post testing of the same group.53,59 In seven of the studies, the population was predominantly or entirely patients with psychotic disorders; the remainder were patients with mood disorders (predominantly bipolar disorder when identified). Studies used varying degrees and types of ICM.

For RCTs, comparators were versions of standard or usual care. Outcomes included number of readmissions,47,51,55,60,61 readmission rates,47,58 and LOS or hospital bed days.47,50,51,55,58,60,61 Each study included secondary outcomes that assessed a variety of satisfaction and quality-of-life measures, four studies assessed clinical engagement and adherence,51,55,58,61 four assessed mental health outcomes (e.g., psychiatric symptom severity),51,55,58,60 one assessed quality of life,61 two studies included cost and health services utilization measures,58,61 and one study assessed housing status.61 Four of the five RCTs reporting the number of readmissions47,51,55,60 found no difference, whereas one found reduced readmissions for those receiving case management.61 Neither of the two studies reporting on readmission rates found differences47 between the two groups. LOS outcomes were inconsistent; two studies showed reduced hospitalization in the ICM group,50,58 and four showed no difference.47,51,55,60,118 In a subgroup analysis, among patients with borderline intelligence, ICM led to reduction in the number of readmissions and hospital bed days.118

For cohort studies, the comparator was standard care or a form of followup care that did not entail ICM. Outcomes included number of readmissions,52,57,62 readmission rates,46,48,49,52,57 and LOS.46,52,56,57,62 Secondary outcome measures included measures of clinical engagement and adherence46,56,62 and cost and health services utilization measures,46,48,56,62 comorbid substance abuse,62 and housing status.62 All three studies evaluating the number of readmissions showed no benefit for the case management group,52,57,62 and one of these showed that the number of readmissions actually increased following case management.52 There was no clear pattern for readmission rates: three studies suggested no benefit49,52,57 and two suggested benefit for the case management group.46,48 Similarly, LOS outcomes were inconsistent: two of the five studies measuring LOS showed decreased LOS for those receiving ICM.46,56 One study showed an increase in LOS.52

For pre-post design studies, outcomes included readmission rates,59 LOS,53,59 and number of readmissions.53 Secondary outcomes included clinical engagement, incarceration, and cost and health services utilization.53 In these two studies, all primary outcomes improved.

##### Collaborative Care

One RCT (three articles)63-65 compared a collaborative chronic care model for patients with bipolar-spectrum disorder versus usual care in a Veterans Administration patient population (Table E-8). Care teams consisting of a psychiatrist and a nurse care coordinator strove to maintain continuity of care with these patients. The study reported readmission rates. Secondary outcomes included measures of mental health, satisfaction, quality of life, and cost and resource utilization. In years 2 and 3, readmission rates tended to be lower among patients receiving collaborative care than for those receiving usual care.

##### Peer Support

One RCT76 compared peer-mentor support plus usual care from those who were themselves in recovery from a mental illness versus usual care (Table E-8). Outcomes included numbers of readmissions and LOS. Secondary outcomes included measures of clinical engagement. Those receiving the peer-mentor support had fewer readmissions and shorter LOS than the usual care group.

##### Psychoeducation

Three studies reported in four manuscripts (Table E-7) assessed effectiveness of inpatient psychoeducation in decreasing psychiatric readmissions for patients with a primary psychotic disorder.77-79,119 Two studies reported in three articles were RCTs,77,78,119 and the other was a retrospective cohort study.79 In each case the psychoeducational intervention was provided for patient and family; two studies compared single family psychoeducation versus routine care,77,79,119 and one study compared psychoeducation in a multiple family group versus single family psychoeducation.78 The followup periods ranged from 4 to 7 years. Outcomes included number of readmissions,77,79,119 readmission rates,77,78,119 and LOS.77,79,119 Secondary outcomes measured included satisfaction with care,79 and both adherence and global assessment of functioning/quality of life.77,119

The two RCTs produced positive findings. The single family psychoeducation intervention produced fewer readmissions, lower readmission rates, and shorter lengths of stay for each year reported throughout the 7-year duration,77,119 and multiple family group psychoeducation appears to produce lower rates of readmission compared with single family educational training.78 In contrast, the single retrospective cohort study found no difference in number of readmissions or length of stay between the two groups.79

##### Various Outpatient Services

One nonrandomized cohort study80 compared patients who could receive any number of services (e.g., medication education, symptom education, service continuity, social relations training, and daily structure) with those who did not receive the services (Table E-8). The population was a cohort of patients with schizophrenia who recently had been admitted to a psychiatric hospital who either did or did not receive the services over a 2-year period. Outcomes included readmission rates. Overall, those receiving symptom education, service continuity, or daily structure had a decreased readmission rate. However, this positive finding was limited to those with 4 or more prior psychiatric hospitalizations; for the subgroup with zero to three prior admissions, no clear benefit was seen with any of the services.