# Background

Repeated hospitalizations on a psychiatric unit, affecting primarily those individuals experiencing serious mental illness, are a substantial problem. In 2010, 29 percent of Medicare-insured psychiatric inpatients from free-standing psychiatric units or general hospital-based psychiatric units had two or more hospitalizations during the same year, and 21 percent were readmitted within 60 days of discharge; most of these patients had psychotic or depressive disorders.1 Similarly, in 2011 in community hospitals (which include both hospital-based psychiatric units and medical/surgical units), mental disorders accounted for the greatest number of all-cause, 30-day readmissions for Medicaid patients 18 to 64 years of age and the second highest number of all-cause 30-day readmissions among those with private insurance (in each case most commonly a psychotic or mood disorder).2 This issue is especially pertinent for those with chronic psychiatric illness who have experienced repeated admissions (i.e., those with two or more prior psychiatric hospitalizations); between 1996 and 2002, 40 to 50 percent of patients with a history of repeated psychiatric hospitalizations were readmitted within 12 months.3-6

Readmissions are costly and disruptive to individuals and families7 and can lead both providers and patients to feeling demoralized or having a sense of failure.8 Although readmissions can result from increased severity of psychiatric illness, ineffective inpatient care, or lack of adherence with outpatient care, in some cases they may be more related to community resource issues such as employment and residential status.9 A decrease in number of psychiatric admissions, typically measured over 30 days, 90 days, or 1 year, is often used as a measure of successful discharge planning and outpatient mental health treatment, but such measures can be confounded by factors such as psychiatric bed availability, readmission penalties, and utilization review policies related to admissions. With increasing pressure to decrease health care costs, reducing hospital bed days (psychiatric or otherwise) is often a key priority for providers and insurers.

Key factors in decreasing the likelihood of subsequent psychiatric admissions include (1) rendering sufficient inpatient care to address adequately the acute presenting problem and stabilize the patient’s psychiatric status;7 (2) ensuring an adequate discharge plan10 and delivery of sufficient support services to transition psychiatric care successfully from an inpatient to an outpatient setting (e.g., discharge services, followup calls, short-term case management, bridge visits, and psychoeducation);11,12 and (3) continuing adequate outpatient services to allow the individual to remain in the community.13-16 Effectively preventing psychiatric readmissions includes providing short-term alternatives to psychiatric rehospitalization in individuals not at significant risk of harm to self or others (e.g., partial hospitalization, crisis residential services, intensive outpatient services) and other longer-term approaches (e.g., assertive community treatment services, involuntary outpatient commitment).

This Technical Brief stems from two important perceptions by clinicians, patients, and often families about inpatient psychiatric care: (1) psychiatric hospital stays have become too brief (in the context of financial pressures and limited outpatient support5) and (2) issues underlying both acute danger to self and others17 and the functional recovery necessary to remain an outpatient are not always addressed,18 so the risk of psychiatric readmission may be only superficially lowered. Little is known about the comparative effectiveness of different lengths of hospital stay for these patients (including circumstances under which shorter [or longer] stays might be more effective), transition support services after discharge, alternatives to psychiatric rehospitalization for those not at risk of harm to self or others, or other approaches to reducing readmissions in individuals.11 Nominators for this Technical Brief are concerned about changes based on the assumption that reducing length of stay (LOS) is efficacious and cost-effective; however, whether such analyses adequately consider short- and long-term costs to different stakeholders, and whether the correct outcomes are being measured, is debatable. Short stays may not permit psychiatric professionals to develop adequate discharge plans, particularly for transitional support. Uncertainty also surrounds the comparative effectiveness and costs of transitional support services, alternatives to psychiatric rehospitalization, and other approaches after discharge. The influence of possible effect modifiers and mediators is unknown. Key contextual variables include treatment adherence, housing stability, quality of life, substance use disorders, involvement in the criminal justice system, clinical engagement, and access to outpatient services.

This Technical Brief identifies and summarizes issues surrounding management strategies to reduce psychiatric hospital readmission (specifically, readmissions to psychiatric units in general hospitals and to psychiatric hospitals). It focuses on those patients who either have a history of multiple psychiatric admissions or are considered at high risk of psychiatric readmission. As a Technical Brief, it does not attempt to summarize the comparative effectiveness of various strategies. Rather, it maps the available evidence on a range of issues for four core components of interventions (management strategies) for patients with psychiatric hospitalizations: LOS for inpatient care, transition support services (i.e., care provided as the individual moves from inpatient to outpatient care), short-term alternatives to psychiatric rehospitalization (i.e., short-term outpatient care provided in place of psychiatric rehospitalization for those not at significant risk of harm to self or others, usually on the order of weeks), and long-term approaches for reducing readmissions (outpatient care generally of a longer duration, usually on the order of months or years).

## Guiding Questions (GQs)

1. Describe core components for management strategies to reduce readmissions: LOS, transition support services, short-term alternatives to rehospitalization, and long-term approaches for reducing readmissions.
  a. For LOS for psychiatric hospitalizations: What are clinically meaningful categorizations of LOS; what are the advantages/disadvantages of different LOSs; how do LOSs vary by patient demographics, diagnosis, and coexisting conditions; and what are the specific harms or safety issues?
  b. For transition support services: What are the different types or modalities of transition support services proposed for or used in clinical practice; what are the advantages/disadvantages of each; how do transition support services vary by patient demographics, diagnosis, and coexisting conditions; and what are the specific harms or safety issues?
  c. For short-term alternatives to rehospitalization: What are the different alternatives to psychiatric rehospitalization that have been proposed or used in clinical practice; what are the advantages/disadvantages of each; how do alternatives to rehospitalization vary by patient demographics, diagnosis, and coexisting conditions; and what are the specific harms or safety issues?
  d. For long-term approaches for reducing psychiatric readmissions: What are the different approaches that have been proposed or used in clinical practice; what are the advantages/disadvantages of each; how do these approaches vary by patient demographics, diagnosis, and coexisting conditions; and what are the specific harms or safety issues?
2. Describe the context in which management strategies are used.
  a. How do these management strategies vary across the United States?
  b. For our primary outcome of interest: how accurate and valid are psychiatric readmissions data? What are other key secondary outcomes to consider for assessing the advantages/disadvantages of the various management strategies?^a^
    a See Table 1.
  c. What kinds of training/certification, staffing, and other resources are required to ensure optimal use of management strategies?
3. Describe current evidence about the effectiveness of these management strategies. What is the effect of each strategy on readmissions and the secondary outcomes?^b^
  b See Table 1.
4. Identify important issues raised by the use of these management strategies for reducing readmissions.
  a. What are other immediate and long-term implications (such as ethical, privacy, equity, or cost considerations) of current length of psychiatric admissions, available transition support services, short-term alternatives to rehospitalization, and long-term approaches for reducing readmissions?
  b. What gaps exist in the current evidence base on these management strategies? What are possible areas of future research?

## Methods

Systematic reviews require some certainty around definitional issues and a body of studies to advance understanding of important issues. Technical Briefs, in contrast, are appropriate products for nascent fields with large uncertainties around definitional issues and limited or no evidence, precisely because they focus on uncertainties in definition, context, and outcomes. A Technical Brief does not attempt to rate the risk of bias of individual studies or grade the strength of the evidence of the literature. The purpose of a Technical Brief is to provide an overview of key issues related to the intervention, such as current indications, relevant patient populations and subgroups of interest, outcomes measured, and contextual factors that may affect decisions regarding the intervention.

For GQs 1, 2, and 4, we reviewed the published and gray literature before the interviews with Key Informants (KIs) and afterwards to substantiate any new insights that the KIs might have provided. We explored points of commonality or departure between KI insights and the published literature in our analysis. We targeted our review of the literature to rely on the best and most recent evidence available to support GQs 1, 2, and 4. For GQ 3, our effectiveness question, we conducted a comprehensive and systematic search of the peer-reviewed and gray literature, and we generated an Evidence Map to describe the available evidence about each management strategy’s ability to reduce readmissions.

Accordingly, we integrated targeted searches of the published literature and gray literature on the nature, context, and future research directions of management strategies to reduce psychiatric readmissions with discussions with KIs. We anticipated that GQs 1 and 2 would be informed primarily by gray literature or nonsystematic published reviews, with KI discussions serving to identify relevant data sources and insights in the absence of evidence. Parts of these questions were also informed by published literature or peer-reviewed data. In instances where evidence from empirical studies informed the response, we first provide a summary of the empirical evidence, followed by a summary of information from other sources. Responses to GQ 3 are based primarily on peer-reviewed, published literature and any relevant gray literature, supplemented by themes from the KI interviews. Responses to GQ 4 are shaped by both the published literature and information from KIs. Our findings are presented in the order of the GQs.

### Literature Review

#### Gray Literature Search

We searched the gray literature to identify information beyond the published literature on management strategies to reduce psychiatric readmissions. Sources for the gray literature included the following: HAPI, OpenSIGLE, ClinicalTrials.gov, WHO International Clinical Trials Registry Platform, Academic Search Complete, NIH RePORTER, and ERIC. We also searched Web sites of the relevant professional associations such as the American Psychiatric Association, the National Alliance on Mental Illness, the National Association of Psychiatric Health Systems, and the National Institute of Mental Health. Appendix A provides a brief description of each of these gray literature sources.

#### Published Literature Search

An experienced research librarian developed our search strategy (Appendix B). Given that contemporary resources, finances, and needs relevant to psychiatric hospitalization have changed substantially from approximately 25 years ago, we systematically searched the published literature from January 1, 1990, through June 23, 2014. We searched in PubMed (MEDLINE), PsycINFO, and the Cochrane Library. We also reviewed the reference lists of relevant papers to identify any relevant citations that our electronic searches might have missed, and we examined any literature suggested by KIs. We conducted updated literature searches on December 12, 2014 that was concurrent with the peer-review process.

#### Eligibility Criteria

Given earlier indications about a limited evidence base from this project’s topic development phase, we carefully considered how best to define our eligibility criteria to both reflect the current state of the art addressing potential management strategies for preventing readmissions (GQs 1, 2, and 4) while considering the current evidence base for the effectiveness of these management strategies (GQ 3).

Our population of interest was adults (≥18 years of age) with repeated psychiatric hospital admissions (a history of two or more) or who were assessed as being at high risk of psychiatric readmission (i.e., selection criteria for a study indicated specifically targeting those who were at high risk of psychiatric readmission). This specification allowed us to focus on those in the repeated risk group, and it excluded studies that may have evaluated relevant management strategies but did not target this population (e.g., excluded studies might sample from a general population of those with psychiatric illness who are at risk of a single psychiatric hospitalization but have not been identified as being at risk of rehospitalization). Our population of interest included subgroups based on diagnosis (e.g., psychotic, mood, or personality disorders), demographics (e.g., elderly, homelessness, race/ethnicity, sex), and comorbidities (e.g., co-occurring medical conditions, developmental disorders, or substance use disorders).

Given that no standard categorization exists for our four groups of management strategies, we used the available literature, our content expertise, and KI input to carefully consider how best to classify each strategy. The categorization of these interventions is listed in Table 1. Eligible interventions included those that fall under our four main categories of management strategies to reduce readmissions: length of stay (e.g., short stay, long stay); transition support services after discharge, which help one successfully move from inpatient treatment to outpatient care and are generally short-term (e.g., transitional discharge services, short-term case management, bridge visits, needs-oriented discharge planning); short-term alternatives to psychiatric rehospitalization in those not at significant risk of harm to self or others, which are also generally short-term (e.g., partial hospitalization, intensive outpatient programs, crisis residential services, respite care); and long-term approaches for reducing psychiatric rehospitalization, which generally require a more extensive and ongoing effort (e.g., Assertive Community Treatment, involuntary outpatient commitment, collaborative care, peer support). We excluded non-English studies to maximize the likelihood of generalizability to our topic nominators’ population of interest.

Table 1 Eligibility criteria

Criterion | Inclusion | Exclusion
Population | All GQs; - Adults (≥18 years) with repeated psychiatric hospital admissions or assessed as being at high risk of psychiatric readmission^a^ including subgroups based on diagnosis (e.g., psychotic, mood, or personality disorders), demographics (e.g., elderly, homelessness, race/ethnicity, sex), and comorbidities (e.g., co-occurring medical conditions, developmental disorders, or substance use disorders) | All GQs; - <18 years; - Single psychiatric hospital admission
Intervention | All GQs; - Varying length of stay for psychiatric hospitalization; - Transition support services after discharge (e.g., supervised discharge, transitional discharge services, needs-oriented discharge planning, short-term case management, bridge visits, computerized decision-support tool for inpatient/outpatient service coordination); - Short-term alternatives to psychiatric rehospitalization (e.g., partial hospitalization, scheduled intermittent hospitalization, intensive outpatient programs, crisis residential services, respite care), generally on the order of weeks; - Long-term approaches for reducing psychiatric rehospitalization (Assertive Community Treatment, involuntary outpatient commitment, case management [both intensive and nonintensive], psychoeducation, various outpatient services, including detoxification, collaborative care, peer support), generally on the order of months or years | All GQs; - Approaches that do not specify the use of at least one of these four core components
Comparator | GQs 1, 2, and 4; - No limitations; GQ 3; - Length of stay for psychiatric hospitalization; a. Different length of stay compared with each other; b. Length of stay compared with one or more variants of the three other management strategies listed above; - Transition support services after discharge; a. Different transition support services compared with each other; b. Transition support services compared with usual care; c. Transition support services compared with one or more variants of the three intervention management strategies listed above; - Short-term alternatives to psychiatric rehospitalization; a. Different short-term alternatives to rehospitalization compared with each other; b. Short-term alternatives to rehospitalization compared with usual care; c. Short-term alternatives to rehospitalization compared with psychiatric rehospitalization; - Long-term approaches to reducing readmissions; a. Different long-term approaches compared with each other; b. Long-term approaches compared with usual care; c. Long-term approaches to reduce readmissions compared with psychiatric rehospitalization | GQs 1, 2, and 4; - Not applicable; GQ 3; - Approaches that do not employ at least one of these comparators
Outcomes | GQs 1, 2, and 4; - No limitations; GQ 3; - Primary outcomes: b; ○ Readmission rates, number of readmissions, length of stay, time to readmission; - Secondary outcomes:; ○ Treatment adherence; ○ Housing stability; ○ Social support; ○ Remission of underlying psychiatric disorder; ○ Physical health outcomes; ○ Quality of life; ○ Clinical engagement; ○ Individual and family feelings about adequately addressing factors prompting the admission; ○ Individual and family felt the stay was sufficient to address safety and dangerousness concerns; ○ Satisfaction with care; ○ Relapse; ○ Criminal justice encounters; ○ Suicide, suicide attempts, other self-injurious behaviors; ○ Homicide and other aggressive behaviors; ○ Relapse into substance use | GQs 1, 2, and 4; - Not applicable; GQ 3; - Outcomes not attributable to the interventions/approaches of interest
Time frames | All GQs; - None | All GQs; - None
Setting | All GQs; - Inpatient or outpatient, primary care or mental health (specialty) care | All GQs; - None
Study design | GQs 1, 2, and 4; - No limitations; GQ 3; - Systematic reviews; - Randomized controlled trials; - Nonrandomized controlled trials; - Prospective and retrospective cohort studies; - Case-control studies; - Single-group pre-post studies | GQs 1, 2, and 4; - Not applicable; GQ 3; - Case reports; - Case series; - Cross-sectional studies; - Opinions; - Commentaries; - Nonsystematic reviews; - Letters to the editor with no primary data
Other | All GQs; - English language; - Published 1990 and later | All GQs; - Non-English language; - Published prior to 1990

GQ = Guiding Question.

a Includes patients with violent behavior

b Studies not reporting on primary outcomes are ineligible for GQ 3.

We developed slightly different criteria for our two sets of questions: GQs 1, 2, and 4 as one set and GQ 3 as the other. For GQs 1, 2, and 4, to ensure that we captured the spectrum of current thinking and evidence for the area, we applied no study design restrictions because we anticipated that relevant information might come from a variety of publications, including review articles, qualitative research, and opinion pieces. Furthermore, we did not require articles to report on outcomes.

We developed stricter eligibility criteria for our review of evidence on the effectiveness of management strategies to prevent readmissions (GQ 3). We required studies to address readmission rates, but we also noted if any of the secondary outcomes of interest were reported (see Table 1). Study designs eligible for GQ 3 included a wide range of designs from systematic reviews to pre-post studies (see Table 1), but case reports, case series, opinions, commentaries, letters to the editor, and nonsystematic reviews were excluded.

Trained members of the research team dually reviewed all abstracts for eligibility based on the pre-established inclusion/exclusion criteria presented in Table 1. Studies marked for possible inclusion by reviewers underwent full-text review. Any study with inadequate information in the abstract also underwent full-text review. We retrieved and reviewed the full text of all articles included during the title/abstract review phase. Trained members of the research team dually reviewed each full-text article for inclusion or exclusion on the basis of the eligibility criteria. Reasons for exclusion were documented and those for inclusion tagged for the relevant GQ that the article addressed. Disagreements about inclusion were resolved by discussion or consensus with review by the full research team as needed.

### Discussions With Key Informants

KIs provide context to empirical findings (or lack of them) and may raise new concerns that prompt additional literature searches. Because we are not surveying a representative sample of KIs, their insights require further empirical exploration, by reviewing our literature searches or performing additional searches of the evidence.

In consultation with our team and the Agency for Healthcare Research and Quality (AHRQ), we identified distinct perspectives that were needed to inform the development of a well-rounded and balanced Technical Brief on management strategies for reducing psychiatric readmissions. Specifically, we sought to recruit KIs representing a spectrum of expertise. We interviewed eight KIs who represented various fields related to psychiatric readmissions: mental health providers (n=3), health services researchers (n=2), policymakers (n=2), and patient advocacy groups (n=1). Some KIs represented multiple fields of expertise. More detail about the KI process is available in Appendix A.

We shared our preliminary GQs and other materials with the KIs prior to the calls. An experienced moderator led the calls following a semistructured guide with built-in places for obtaining input from the KIs. Insights from KIs were used to confirm the findings from our literature review and the scope of our Technical Brief. Specifically, we focused on the preliminary GQs (specifically, GQ 1: description of core components for management strategies to reduce readmissions; GQ 2: context in which management strategies are used; and GQ 4: key important issues raised by the use of these management strategies for reducing readmissions), using the subquestions for each GQ as prompts to discuss issues further.

### Data Management and Abstraction

All literature screening results were tracked in the EndNote database. We recorded the reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix C). We abstracted data into a standardized template from any studies that met our inclusion criteria for GQ 3. For each study, we captured study characteristics (study design, interventions, comparators, sample size, duration, sample size, country, and setting), population characteristics (types of serious mental illness, comorbid substance abuse, number of repeated hospitalizations, comorbid developmental disorders, comorbid medical conditions, homelessness, age, sex, race), and outcomes (data on readmission rates, listing of other outcomes of interest reported). One member of the research team collected the data, and a second team member reviewed it for accuracy and completeness.

### Peer Review and Public Comment

The draft report was available for peer review and public comment at www.effectivehealthcare.ahrq.gov from December 1 to December 29, 2015. Two individuals or organizations offered public comment. In addition, nine peer reviewers provided us with feedback on the draft report. We revised the report in response to these comments where appropriate.