# Characteristics and Outcomes for Management Strategies

Table E-1 Characteristics and outcomes for length of stay (LOS) studies

Citation Design Sample Size Length of Followup | Population: Diagnosis types, mean prior hospitalizations country, setting | Intervention | Comparator(s) | Outcomes | Results
Appleby et al., 1993^1^ Cohort (Retrospective) 1,500 18 months | All psychotic disorder patients 5.4 US, inpatient | ≤7 days (n=316) | 8-14 days (n=352); 15-30 days (n=343) 31-60 days (n=232); >60 days (n=257 | Readmission rate | Shorter hospital stay groups (≤14 days) produced higher readmission rates at 1 and 18 months
Appleby et al., 1996^2^ Cohort (retrospective) 165 12 months | All psychotic disorder patients 11 US, inpatient | Long-stay unit (mean of 69 days) (n=55) | Shorter-stay units (means of 32 to 35 days); (n=55; n=55) | Number of readmissions | Number of readmissions did not differ by LOS

LOS = length of stay; US = United States.

Table E-2 Characteristics and outcomes for transitional support service studies

Citation Design Sample Size Length of Followup | Population: Diagnosis Types, Mean Prior Hospitalizations Country, Setting | Intervention | Comparator(s) | Outcomes | Results
Aftercare services Barekatain et al., 2014^3^ RCT 123 1 year | All psychotic or bipolar disorder patients (schizophrenia, schizoaffective disorder, or bipolar I disorder with mania or mixed subtype) ≥2 Iran, outpatient | Defined aftercare (follow-up phone calls and home visits to prompt adherence) and psychoeducation program for family members (n=61) | Usual care (n=62) | Number of readmissions | Aftercare services led to a lower number of readmissions at 12-month follow-up than usual care.
Aftercare services Lay et al., 2014^75^ RCT 238 1 year (total duration is 2 years, but study in progress) | Patients with substance use, mood, psychotic, stress-related, and personality disorders 8.5 to 9.3 Switzerland, outpatient | Combined individualized transitional psychoeducation and long-term preventive monitoring (n=138) | Treatment as usual (n=138) | Number of readmissions (voluntary and compulsory) Readmission rates (voluntary and compulsory) LOS (voluntary and compulsory) | Patients receiving the psychoeducation and long-term preventive monitoring intervention had a lower rate of compulsory readmission than those receiving treatment as usual. The intervention group also trended toward lower rates and LOS of compulsory readmissions than the treatment as usual group.
Computerized decision support tool Schmidt-Kraepelin et al., 2009^4^ Non-randomized controlled study 93 12 months | All psychotic disorder patients 7.3 Germany, outpatient, MH/specialty care | Complex decision support intervention (n=46) | Treatment as usual (n=47) | Number of readmissions Readmission rate LOS (overall, voluntary, involuntary) | Decision support tool group had decreased number of readmissions and readmission rate. No differences in LOS when readmitted, although a trend toward decreased LOS seen in the decision support group.
Needs-oriented discharge planning Puschner et al., 2011^5^ Puschner et al., 2008^6^ RCT 491 18 months | All psychotic and mood disorder patients 2.9 Germany, inpatient, MH/specialty care | Needs-oriented discharge planning and monitoring (n=241) | Treatment as usual (n=250) | Readmission rate LOS | No between-group differences in readmission rates or LOS when readmitted.
Supervised discharge Davies et al., 2001^7^ Davies et al., 1999^8^ Single-group pre-post 22 3 years | Mostly psychotic disorder patients and some diagnosed with mood disorders 7.3 UK, outpatient | Supervised discharge (n=22) | Unsupervised discharge (n=22) | Number of readmissions LOS | Supervised discharge appeared to produce fewer readmissions and decreased LOS when readmitted

Table E-3 Characteristics and outcomes for short-term alternatives to psychiatric rehospitalization studies

Citation Design Sample Size Length of Followup | Population: Diagnosis Types, Mean Prior Hospitalizations Country, Setting | Intervention | Comparator(s) | Outcomes | Results
Dilonardo et al., 1998^9^ RCT 57 24 months | Primarily psychotic, mood, and anxiety disorder patients with co-morbid polysubstance use disorders 5.04 US, inpatient | Scheduled intermittent hospitalization (4 admissions per year, each lasting 9-11 days and scheduled 11-13 weeks apart) (n=26) | Unplanned emergency hospitalizations or standard care (n=31) | Number of unplanned readmissions Hospital bed-days | No between-group differences in number of unplanned readmissions or hospital bed-days.
Fenton et al., 1998^10^ Fenton et al., 2002^11^ RCT 119 6 months | Psychotic, mood, personality, and other disorder patients 12 to 14 US, outpatient, MH/specialty care | Residential crisis care (n=69) | Admission to psychiatric hospital (n=50) | Readmission rate LOS | Readmission rates did not differ between groups. Partial hospitalization group experienced longer average LOS when readmitted.
Dummont et al., 2002^12^ RCT 265 12 months | All patients with a DSM-III R diagnosis NR, but majority had ≥4 US, MH/specialty care | Access to crisis residential service plus usual service (n = NR) | Usual service (n = NR) | Readmission rate | Lower readmission rate in crisis residential service group at 6 and 12 months than in the usual service group.
Merchant et al., 1994^13^ Single-group pre-post (retrospective) 44 2 to 5 years | PTSD, psychotic disorder, and mood disorder patients 0.9 overall and 1.9 unplanned admissions per year US, MH/specialty care | Tune Up Program (planned hospitalizations) (n=44) | Pre-Program (n=44) | Number of readmissions Number of unplanned readmissions LOS | After patients began planned hospitalizations (Tune Up), the number of planned readmissions increased, while both the number of unplanned readmissions and the LOS decreased.

LOS = length(s) of stay; MH = mental health; n = number of participants; NR = not reported; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; US = United States

Table E-4 Characteristics and outcomes for ACT studies

Citation Design Sample Size Length of Followup | Population: Diagnosis Types, Mean Prior Hospitalizations Country, Setting | Intervention | Comparator(s) | Outcomes | Results
Bond et al., 1990^14^ RCT 88 12 months | Primarily psychotic and mood disorder patients ≥5 US, outpatient | ACT (n=45) | Drop-in centers supplemented by aftercare services (n=43) | Number of readmissions Readmission rates LOS Hospital bed-days | For state hospitals, the ACT group had fewer 12-month hospital readmissions and hospital bed-days than drop-in center patients. However, the ACT group experienced no change in the average LOS when readmitted, and there was no difference in readmission rates. For private hospitals, no differences in the number of readmissions, readmission rates, or LOS.
Botha et al., 2010^15^ RCT 60 12 months | All psychotic disorder patients ≥2 South Africa, inpatient, outpatient, MH/Specialty Care | ACT (n=34) | Control group (n=26) | Number of readmissions Readmission rates Hospital bed-days | The ACT group had lower numbers of readmissions, smaller readmissions rates, and fewer hospital bed-days than the control group.
Botha et al., 2014^16^ RCT 60 12 months | All psychotic disorder patients ≥4 South Africa, inpatient, outpatient, MH/specialty care | Modified ACT (N=34) | Standard care (community mental health care) (n=26) | Number of readmissions Hospital bed-days | ACT group experienced fewer 36-month readmissions and decreased hospital bed-days than the standard care group.
Essock & Kontos, 1995^17^ RCT 262 12 months | Nearly all psychotic and mood disorder patients, some diagnosed with other Axis I disorders NR, but patients identified as high risk of readmission US, inpatient, outpatient, MH/specialty care | ACT (n=NR) | Standard case management (n=NR) | Proportion of days hospitalized (a variation of hospital bed-days) | The ACT group spent about half as much time hospitalized during 12 month followup as standard case management clients.
Sytema et al., 2007^18^ RCT 118 3 to 12 months | Primarily psychotic, mood, and delusional disorder patients 3.1 to 4.2 The Netherlands, outpatient | ACT (n=59) | Standard community mental health control (n=59) | Number of readmissions Hospital bed-days | No between-group differences in number of readmissions, hospital bed-days in a psychiatric hospital, or hospital bed-days in closed wards.
Bond et al., 1991^19^ Cohort (prospective) 31 2 years | Patients mostly diagnosed with psychotic disorders 2.6 to 2.7 US, outpatient | ACT (team ICM) (n=29) | Senior case management (individual ICM) (n=10) | Number of readmissions Readmission rate Hospital bed-days | No between-group differences overall in number of readmissions, but over time there was a trend for declining hospital readmissions for ACT clients vs. an alternating decreasing and increasing pattern for Senior Case Manager clients. ACT group had a lower readmission rate, but no difference in hospital bed-days, than the Senior Case Management group.
Hamernik et al., 1999^20^ Non-randomized controlled trial 38 12 months | Nearly all psychotic and mood disorder patients 3.19 to 5 Australia, inpatient, outpatient, MH/specialty care | ACT (n=18) | Standard case management (n=20) | Readmission rates Hospital bed-days | No between-group differences in 12-month readmission rates or hospital bed-days during readmissions, although both groups experienced reductions.
Liem et al., 2013^21^ Cohort (prospective with historical control) 24 months | Primarily psychotic, mood or anxiety, or personality or substance use disorder patients 3.6 to 3.7 Hong Kong, outpatient | ACT (n=70) | Usual care (n=70) | Number of readmissions Readmission rate Hospital bed-days (overall, voluntary, involuntary) | ACT group had greater reduction in number of readmissions, readmission rates, and hospital bed-days than the usual care group
Dincin et al., 1993^22^ Single-group pre-post (prospective or retrospective, type unclear) 66 12 months | Patients with mostly psychotic disorders and also major affective disorder ≥3 US, outpatient, MH/specialty care | ACT (n=66) | Pre-ACT (n=66) | Readmission rate Hospital bed-days | After ACT, the sample demonstrated a reduction in state hospital readmissions and fewer hospital bed-days.
Tibbo et al., 1999^23^ Single-group pre-post (retrospective) 295 12 months | Patients with mixture of psychotic, mood, personality, and other disorders 1.26 Canada, outpatient | ACT (n=295) | Pre-ACT (n=295) | Readmission rate Hospital bed-days | After ACT, the sample demonstrated lower readmission rate and lower average number of hospital bed-days.
Udechuku et al., 2005^24^ Single-group pre-post 43 12 months | Nearly all psychotic disorder patients with a single case of mood disorder and several comorbid personality and anxiety disorders 0.8; identified at high risk of readmission Australia, outpatient | ACT (n=43) | Pre-ACT (n=43) | Readmission rate LOS | After ACT, readmission rate trended toward being lower, and the average LOS during readmissions decreased.
Dietzen et al., 1993^25^ Secondary analysis of earlier study data 155 Study duration NR | Sample of patients with more than half diagnosed with psychotic disorders (other diagnoses NR) 10.6 US, MH/specialty care | ACT, 7 unique programs in Chicago, Indiana, Philadelphia (n=155) | Pre-ACT (n=155) | Hospital bed-days | After ACT, no differences in hospital use across sites. Four programs with moderate or substantial impact in reducing hospital days also had moderate to high levels of service intensity. Three programs with minimal impact on hospital use had moderate to low service intensities.

ACT = assertive community treatment; ICM = intensive case management; LOS = length(s) of stay; MH = mental health; NR = not reported; RCT = randomized controlled trial; US = United States.

Table E-5 Characteristics and outcomes for OPC/CTO studies

Citation Design Sample Size Length of Followup | Population: Diagnosis Types, Mean Prior Hospitalizations Country, Setting | Intervention | Comparator(s) | Outcomes | Results
Burns et al., 2013^26^ OCTET RCT 336 12 months | All psychotic disorder patients Median of 5-6 UK, outpatient | CTO (n=167) | Section 17 (a rehabilitation practice, used for brief periods to assess the stability of a patient’s recovery after or during a period of involuntary hospital treatment) (n=169) | Readmission rate Hospital bed-days | No between-group differences in readmission rate or hospital bed-days.
Steadman et al., 2001^27^ RCT 142 3 years | Primarily patients with psychotic disorders, many with co-occurring substance use disorders NR, but all patients identified as having high risk of multiple readmissions US, outpatient | OPC in addition to enhanced service package (n=78) | Enhanced service package only (n=64) | Readmission rate Hospital bed-days | No between-group differences in readmission rates or hospital bed-days.
Swartz et al., 1999^28^ Compton et al., 2003^29^ RCT 264 12 months | Psychotic and mood disorder patients 1.4 to 1.5 US, outpatient | OPC (standard or extended, meaning ≥180 days) (n=129)^a^ | Release from outpatient commitment (n=135)^b^ | Number of readmissions Readmission rate Hospital bed-days | No between-group differences in number of readmissions, readmission rates, or hospital bed-days. However, among psychotically disordered individuals, extended outpatient commitment reduced hospital readmissions when combined with a higher intensity of outpatient treatment.
Segal et al., 2006^30-33^ Cohort (retrospective) 24,973 Up to 10 years | Patients diagnosed with psychotic, mood, dementia, and other disorders 3.0 Australia, outpatient | CTO (n=8,879) | Not placed on CTO (n=16,094) | Number of readmissions LOS Hospital bed-days | Patients on CTOs as a requirement for conditional release had more readmissions and hospital bed-days but also a decrease in the average LOS of inpatient stays. Fewer readmissions, fewer hospital bed-days, and shorter LOS when CTO initiated as part of conditional release during first hospitalization versus later hospitalization or not at all. Patients had fewer hospital bed-days when issued CTOs initiated in the community versus in the hospital or a combination of both. Following community treatment under extended CTOs (i.e., ≥180 days), patients had fewer readmissions and hospital bed-days than those on extended (i.e., ≥180 days) voluntary outpatient treatment.
Swartz et al., 2010^34^ Cohort (retrospective) 3,576 1 year | Patients diagnosed with schizophrenia, mood disorders, and other disorders NR, but patients at high risk of readmission US, outpatient | OPC in combination with ICM (n=NR) OPC in combination with ACT (n=NR) Short-term OPC (0-6 months) (n=NR) Long-term OPC (7-12 months) (n=NR) | ACT alone (n=NR) Pre-OPC (n=NR) | Readmission rate Hospital bed-days | OPC in combination with ICM or ACT led to a lower rate of readmission than ACT alone. Both short- and long-term OPCs led to reduced readmission rates and hospital bed-days compared with the pre-OPC period.
Vaughan et al., 2000^35^ Cohort (retrospective) 246 12-60 months | All psychotic disorder patients, 5.17 to 6.24 Australia, outpatient | CTO (n=123) | Matched control (n=123) | Readmission rate | Readmission rates for those on CTO tended to be higher than those of the control group.
Geller et al., 1998^36^ Cohort (prospective or retrospective, type unclear) 38 6 months | Primarily patients with schizophrenia (other diagnoses NR) 1.53 to 1.63 US, outpatient | OPC (n=19) | Pre-OPC (19) Matched controls (n=19) | Number of readmissions Hospital bed-days | No between-group differences in the number of readmissions or hospital bed-days after OPC, although OPC and matched control groups experienced similar reductions in both outcomes.
Kisely et al., 2013^37^ Case-control 5,916 1 year | Patients primarily diagnosed with psychotic disorders and less frequently with mood disorders 1.74 to 1.78 Australia, outpatient, MH/specialty care | CTO (n=2,958) | Control group (not on CTO) (n=2,958) | LOS | CTO patients and the control group experienced similar decreases in LOS when readmitted.
Segal et al., 2006^38^ Case-control 1,182 2 years | Nearly all psychotic disorder patients with some also diagnosed with major affective and personality disorders 37.2 to 56.3 inpatient days per year before index admission Australia, outpatient | CTO (n=591) | Control (patients not placed on CTO) (n=591) | Number of readmissions LOS Hospital bed-days | Patients with CTOs had greater decreases in the number of readmissions, LOS, and hospital bed-days.
Christy et al., 2009^39^ Single-group pre-post (retrospective) 50 2 years | Patient diagnoses NR NR, but patients at high risk of readmission US, outpatient | OPC (n=50) | Pre-OPC (n=50) | Number of readmissions (involuntary emergency and state hospital) | OPCs led to a decrease in involuntary emergency readmissions compared with the pre-OPC period. The effect of OPCs on state hospital readmissions was unclear.
Fernandez et al., 1990^40^ Single-group pre-post 4,179 3 years | Psychotic, mood, personality, and other disorder patients 3.69 US, outpatient | OPC (n=4,179) | Pre-OPC (n=4,179) | Number of readmissions Hospital bed-days | After placement on CTO, number of readmissions and hospital bed-days decreased.
Greenberg et al., 2005^41^ Single-group pre-post (prospective) 26 3 to 5 years | Primarily patients with psychotic disorders, but also some with mood, personality, and comorbid substance use disorders 2.4 Israel, outpatient | OPC (n=26) | Pre-OPC (n=26) | Number of readmissions Hospital bed-days | After placement on CTO, number of readmissions and hospital bed-days decreased. Patients regularly attending treatment while on CTOs experienced a trend toward a greater reduction in hospital bed-days compared with non-adherent patients on CTOs.
Kallapiran et al., 2010^42^ Single-group pre-post (prospective) 28 1 year | Primarily patients with schizophrenia or related disorders 2.5 Australia, outpatient | CTO (n=26) | Pre-CTO (n=26) | Number of readmissions Hospital bed-days | Following use of CTOs, the number of readmissions per annum and hospital bed-days fell, when the index hospitalization was included. Excluding the index hospitalization, neither outcome differed after use of CTOs.
Munetz et al., 1996^43^ Single-group pre-post (retrospective) 20 At least 12 months outpatient commitment | Primarily patients with schizophrenia, schizoaffective, and bipolar disorders, as well as some with co-morbid substance abuse histories 12.9 US, outpatient | OPC (n=20) | Pre-OPC (n=20) | Number of readmissions Hospital bed-days | Mean number of readmissions decreased with OPC in State hospitals, but not for those in General Hospitals. Mean number of hospital bed-days decreased with OPC in both hospital types.
Nakhost et al., 2012^44^ Single-group pre-post (retrospective) 72 2 to 10 years | Primarily patients with psychotic disorders, but also some with mood disorders and co-morbid personality disorders 2.85 Canada, outpatient | CTO (n=72) | Pre-CTO (n=72) | Readmission rate | After placement on CTO, readmission rate decreased.
O’Brien et al., 2005^45^ Single-group pre-post (retrospective) 25 12 months | Primarily patients with psychotic disorders, but also some with mood disorders and co-morbid anxiety, personality, and substance use disorders 1.96 (range: 1 to 4) Canada, outpatient | CTO (n=25) | Pre-CTO (n=25) | Number of readmissions Hospital bed-days | After placement on CTO, number of readmissions and hospital bed-days decreased.
Rohland et al., 1998^46^ Single-group pre-post (retrospective) 81 12 months | Patients with psychotic disorders, bipolar affective disorders, MDD with psychosis, and psychotic disorders 1.3 US, Outpatient | OPC (n=81) | Pre-OPC (n=81) | Number of readmissions LOS Hospital bed-days | OPC significantly reduced the number of readmissions, LOS when readmitted, and hospital bed-days.
Zanni et al., 2007^47^ Single-group pre-post (retrospective) 193 2 years | Patient diagnoses NR 4.25 US, outpatient | OPC (n=115) | Pre-OPC (n=115)^c^ | Readmission rate LOS Hospital bed-days | After placement on OPC, readmission rates decreased, and LOS and hospital bed-days remained similar compared with the pre-CTO period.

a In Elbogen et al., 2003,^48^ available n = not reported, but overall N available for analysis of financial coercion = 258. In Swanson et al., 2001^49^ available n = 148 and overall N available for analysis of patients with histories of both arrest and psychiatric hospitalization = 262.

b In Elbogen et al., 2003,^48^ available n = not reported, but overall N available for analysis of financial coercion = 258. In Swanson et al., 2001^49^ available n = 114 and overall N available for analysis of patients with histories of both arrest and psychiatric hospitalization = 262.

c This study47 also included a control group of patients with at least one prior psychiatric admission between 1995 and 1997, like the OPC group. However, there was no indication that the control group was at high risk of multiple psychiatric admissions. We therefore could only use pre-post data for the OPC group.

CTO = compulsory treatment order(s); ICM = intensive case management; LOS = length(s) of stay; MDD = major depressive disorder; MH = mental health; n = number of participants; N = overall sample; OCTET = Community Treatment Orders for Patients with Psychosis Trial; OPC = involuntary outpatient commitment; RCT = randomized controlled trial; UK = United Kingdom; US = United States.

Table E-6 Characteristics and outcomes for case management studies

Citation Design Sample Size Length of Followup | Population: Diagnosis Types, Mean Prior Hospitalizations Country, Setting | Intervention | Comparator(s) | Outcomes | Results
Burns et al., 1999^50^ Tyrer et al., 1999^51^ RCT 708 2 years | All psychotic disorder patients ≥2 UK, MH/specialty care | ICM (n=353) | Standard case management (n=355) | Number of readmissions Hospital bed-days | No between-group differences in number of readmissions or hospital bed-days in the overall sample. However, ICM led to reductions in number of readmissions and hospital bed-days among patients with borderline intelligence.
Bush et al., 1990^52^ RCT 28 12 months | All patients meeting criteria for severe psychiatric disability and diagnosed with schizophrenia, bipolar disorder, or personality disorders 2 to 18. US, various settings (home, jail, inpatient, community) | ICM (n=14) | Standard case management (n=14) | Number of readmissions Hospital bed-days | ICM resulted in a greater decrease in number of hospital admissions and hospital bed-days than standard case management.
Chan et al., 2000^53^ RCT 62 11 months | All psychotic disorder patients ≥3 China, outpatient | Case management (n=31) | Traditional community psychiatric nursing (CPN) care (n=31) | Readmission rate (unplanned) Hospital bed-days (unplanned) | No between-group difference in unplanned readmission rates. However, case management led to fewer hospital bed-days (1 patient) than traditional care (1 patient).
Harrison-Read et al., 2002^54^ RCT 193 2 years | Primarily psychotic and mood disorder patients, with some personality or other disorders 5.4 to 5.6 UK, outpatient | ICM (enhanced community management) (n=97) | Usual care (n=96) | Number of readmissions LOS Hospital bed-days | No between-group differences in number of readmissions hospital bed-days. However, ICM led to shorter LOS when readmitted than usual care.
Lichtenberg et al., 2008^55^ RCT, with a third nonrandomized group 370 12 months | Mostly patients with psychotic disorders, but also some with mood, personality, and other disorders 12 to 12.9 Israel, outpatient | ICM (clinical case management) (n=122) | Standard care (n=95) No treatment (nonrandomized) (n=153) | Number of readmissions Readmission rate Hospital bed-days | No between-group differences in number of readmissions, readmission rate, or hospital bed-days.
Muijen et al., 1994^56^ RCT 82 18 months | All psychotic or affective psychotic disorder patients ≥2 UK, MH/specialty care, primary care | ICM (intensive aftercare) (n=41) | Generic aftercare (CPN) (n=41) | Number of readmissions LOS | No between-group differences in number of readmissions or LOS when readmitted.
Quinlivan et al., 1995^57^ RCT 90 2 years | Nearly all psychotic and mood disorder patients ≥3 US, MH/specialty care | ICM (n=30) | Traditional case management (n=30) Standard care (n=30) | LOS | ICM group had shorter LOS compared with standard care. ICM group had a trend toward shorter LOS compared with traditional case management.
Schmidt et al., 2008^58^ Non-randomized controlled trial 142 Follow-up NR | Primarily patients with psychotic and affective disorders, as well as adjustment and personality disorders and co-morbid substance abuse disorders NR, but all patients identified as having history of multiple admissions US, setting NR | Case management with consumer provider (n=75) | Case management without consumer provider (n=67) | Number of readmissions Readmission rate Hospital bed-days | No between-group differences in readmission rates or numbers of readmissions. Results for hospital bed-days NR.
Hornstra et al., 1993^59^ Cohort (retrospective) 224 24 months | All psychotic disorder patients 3.46 to 3.83 US, outpatient | ICM (n=112) | Traditional case management (n=112) | Number readmissions Readmission rate Hospital bed-days | No between-group differences in number of readmissions, readmission rate, or hospital bed-days.
Kolbasovsky et al., 2009^60^ Cohort (retrospective) 652 1 month | Nearly all psychotic and mood disorder patients NR, all patients identified by predictive model61 as having high risk of readmission in next year US, outpatient | ICM (n=305) | Historical control group (no ICM) (n=347) | Readmission rate Hospital bed-days | ICM group had a lower 30-day readmission rate and fewer hospital bed-days than the historical control group.
Kolbasovsky et al., 2010^62^ Non-randomized controlled trial (historical controls used) 596 6 months | Primarily psychotic and bipolar disorder patients identified by predictive model61 as having high risk of readmission in next year US, outpatient | ICM (n=290) | Historical control group (no ICM) (n=306) | Readmission rate Hospital bed-days | ICM group had lower readmission rate than the historical control group. Results for hospital bed-days unclear.
Parson et al., 1999^63^ Cohort (prospective or retrospective, type unclear) 60 Study duration NR | Patients diagnosed primarily with psychotic, mood, and adjustment disorders NR, but patients identified as having high risk of multiple admissions US, outpatient | Case management (n=24) | No case management (n=36) | Readmission rate | No between-group difference in readmission rate.
Preston et al., 2000^64^ Cohort (retrospective) 160 2 years | Primarily psychotic, mood, and affective disorder patients and some diagnosed with not otherwise specified conditions ≥2 Australia, outpatient | ICM (n=80) | Matched control (n=80) | Hospital bed-days | ICM group had fewer hospital bed-days at both 1 and 2 years post-treatment compared with controls.
Rothbard et al., 2012^65^ Cohort (prospective) 176 12 months | Almost all patients diagnosed with psychotic and mood disorders 5.4 to 5.6 US, inpatient, outpatient, MH/specialty care | ICM (high end user enhanced transition support and case coordination program) (n=61) | Usual care (n=115) | Number of readmissions Readmission rate Hospital bed-days | ICM group had a greater number of readmissions, a higher readmission rate, and more hospital bed-days than the usual care group.
Husted et al., 2000^66^ Single-group pre-post (prospective) 59 11 months to 10.8 years | All patients with psychotic disorders, bipolar affective disorder, recurrent MDD, or borderline personality disorder and/or ≥2 inpatient hospitalizations in last 24 months 1.8 per year US, outpatient, MH/specialty care | ICM (community support program [CSP]) (n=59) | Pre-CSP (n=59) | Readmission rate Hospital bed-days | After participation in CSP program, readmission rate and hospital bed-days decreased.
Mahendran et al., 2006^67^ Single-group pre-post (retrospective) 227 12 months | Patients diagnosed almost entirely with psychotic and mood disorders NR, but all patients at high risk of multiple admissions Singapore, inpatient, outpatient | Case management (hospital-based) (n=227) | Pre-case management (n=227) | Number of readmissions LOS Hospital bed-days | After participation in hospital-based case management group, number of readmissions, LOS, and hospital bed-days all decreased.

CPN = community psychiatric nurse(s); CSP = community support programs; HCPS = hospital-based community psychiatric service; ICM = intensive case management; LOS = length of stay(s); MDD = major depressive disorder; MH = mental health; n = number of participants; NR = not reported; RCT = randomized controlled trial; UK = United Kingdom; US = United States.

Table E-7 Characteristics and outcomes for psychoeducation studies

Citation Design Sample Size Length of Followup | Population: Diagnosis Types, Mean Prior Hospitalizations Country, Setting | Intervention | Comparator(s) | Outcomes | Results
McFarlane et al., 1995^68^ RCT 41 4 years | All psychotic disorder patients 3.9 US, MH/specialty care | Psychoeducational multiple-family group (n=16) | Psychoeducational single-family treatment (n=18) Family-dynamic, multiple-family group (n=7) | Readmission rates | Multiple-family group more effective in decreasing readmission rates than single-family treatment, but similar to family-dynamic, multiple-family group.
Pitschel-Walz et al., 2006^69^ Bauml et al., 2007^70^ Munich Psychosis Information Project Study RCT 236 7 years | All psychotic disorder patients 4 Germany, inpatient, outpatient | Psychoeducational group meetings for patients and relatives + routine treatment (n=125) | Routine treatment (n=111) | Number of readmissions Readmission rate Hospital bed-days | Psychoeducation group had fewer readmissions, lower readmission rate, and fewer hospital bed-days than the routine treatment group.
de Groot et al., 2003^71^ Cohort (retrospective) 54 7 years | All psychotic disorder patients 2.5 to 2.8 Australia, outpatient | Psychoeducation program for families (n=27) | No program (matched control) (n=27) | Number of readmissions Hospital bed-days | No between-group differences in number of readmissions or hospital bed-days.

LOS, length of stay; MH, mental health; n = number of participants; RCT, randomized controlled trial; UK, United Kingdom; US, United States.

Table E-8 Characteristics and outcomes for other long-term approaches in high-risk individuals

Citation Design Sample Size Length of Followup | Population: Diagnosis Types, Mean Prior Hospitalizations Country, Setting | Intervention | Comparator(s) | Outcomes | Results
Collaborative care Bauer et al., 2006^72^ Bauer et al., 2006^73^ Bauer et al., 2001^74^ Cooperative Studies Program 430 Study RCT 330 3 years | All bipolar disorder patients 5.3 US, MH/specialty care | Bipolar Disorder Program (n=166) | Usual care (n=164) | Readmission rates Hospital bed-days | Bipolar Disorder Program group’s readmission rates in years 2 and 3 tended to be lower than those of the usual care group. There was no between-group difference in hospital bed-days.
Peer support Sledge et al., 2011^76^ RCT 74 9 months | NR for sample, but inclusion criteria required a diagnosis of schizophrenia, schizoaffective disorder, psychotic disorder not otherwise specified, bipolar disorder, or MDD 3.76 to 3.94 US, outpatient | Peer mentor support plus usual care (n=38) | Usual care (n=36) | Number of readmissions Hospital bed-days | Peer mentor support group had fewer readmissions and hospital bed-days than the group receiving usual care alone.
Various outpatient services Prince, 2006^77^ Cohort (prospective or retrospective, type unclear) 315 3 months | All psychotic disorder patients NR, but nearly three-fourths of patients had ≥3 prior admissions US, outpatient | Various outpatient community treatment services (i.e., medication education, symptom education, care continuity, social relations training, daily structure, daily living training, or kin involvement) (n=NR) | Individual services not received (n=NR) | Readmission rate | Overall, those receiving symptom education, service continuity, or daily structure had a decreased readmission rate. However, for the subgroup with 0-3 prior admissions, no clear benefit was seen with any of the services.

LOS = length(s) of stay; MDD = major depressive disorder; MH = mental health; n = number of participants; NR = not reported; RCT = randomized controlled trial; US = United States

## Appendix E References

1 Appleby L, Desai PN, Luchins DJ, et al. Length of stay and recidivism in schizophrenia: a study of public psychiatric hospital patients. Am J Psychiatry. Jan. 1993;150(1):72-6. Epub: 1993/01/01. [pmid: 8417584].
2 Appleby L, Luchins DJ, Desai PN, et al. Length of inpatient stay and recidivism among patients with schizophrenia. Psychiatr Serv. Sep. 1996;47(9):985-90. Epub: 1996/09/01. [pmid: 8875666].
3 Barekatain M, Maracy MR, Rajabi F, et al. Aftercare services for patients with severe mental disorder: A randomized controlled trial. J Res Med Sci. 2014;19(3):240-5. [pmid: 24949032].
4 Schmidt-Kraepelin C, Janssen B, Gaebel W. Prevention of rehospitalization in schizophrenia: results of an integrated care project in Germany. Eur Arch Psychiatry Clin Neurosci. Nov. Suppl 2. 2009;259:S205-12. Epub: 2009/11/13. [pmid: 19876680].
5 Puschner B, Steffen S, Völker KA, et al. Needs-oriented discharge planning for high utilisers of psychiatric services: Multicentre randomised controlled trial. Epidemiol Psychiatr Sci. 2011;20(2):181-92. [pmid: 21714365].
6 Puschner B, Steffen S, Gaebel W, et al. Needs-oriented discharge planning and monitoring for high utilisers of psychiatric services (NODPAM): design and methods. BMC Health Serv Res. 2008;8:152. Epub: 2008/07/23. [pmid: 18644110].
7 Davies S, Fallow S, Bruce J, et al. Early outcomes of supervised discharge. Med Sci Law. Jan. 2001;41(1):31-4. Epub: 2001/02/24. [pmid: 11219120].
8 Davies S, Bruce J, Fallows S. Section 25 aftercare under supervision: the first eighteen months' experience. Med Sci Law. Jul. 1999;39(3):214-8. Epub: 1999/08/31. [pmid: 10466315].
9 Dilonardo JD, Connelly CE, Gurel L, et al. Scheduled intermittent hospitalization for psychiatric patients. Psychiatr Serv. Apr. 1998;49(4):504-9. Epub: 1998/04/29. [pmid: 9550241].
10 Fenton WS, Mosher LR, Herrell JM, et al. Randomized trial of general hospital and residential alternative care for patients with severe and persistent mental illness. Am J Psychiatry. Apr. 1998;155(4):516-22. Epub: 1998/04/18. [pmid: 9545998].
11 Fenton WS, Hoch JS, Herrell JM, et al. Cost and cost-effectiveness of hospital vs residential crisis care for patients who have serious mental illness. Arch Gen Psychiatry. Apr. 2002;59(4):357-64. Epub: 2002/04/03. [pmid: 11926936].
12 Dummont JM, Jones K. Findings from a consumer/survivor defined alternative to psychiatric hospitalization. Outlook. 2002;(Spring):4-6.
13 Merchant DJ, Henfling PA. Scheduled brief admissions: patient "tuneups". J Psychosoc Nurs Ment Health Serv. Dec. 1994;32(12):7-10. Epub: 1994/12/01. [pmid: 7714856].
14 Bond GR, Witheridge TF, Dincin J, et al. Assertive community treatment for frequent users of psychiatric hospitals in a large city: a controlled study. Am J Community Psychol. Dec. 1990;18(6):865-91. Epub: 1990/12/01. [pmid: 2091459].
15 Botha UA, Koen L, Joska JA, et al. Assessing the efficacy of a modified assertive community-based treatment programme in a developing country. BMC Psychiatry. 2010;10:73. Epub: 2010/09/17. [pmid: 20843301].
16 Botha UA, Koen L, Galal U, et al. The rise of assertive community interventions in South Africa: A randomized control trial assessing the impact of a modified assertive intervention on readmission rates; a three year follow-up. BMC Psychiatry. 2014;14(1).
17 Essock SM, Kontos N. Implementing assertive community treatment teams. Psychiatr Serv. Jul. 1995;46(7):679-83. Epub: 1995/07/01. [pmid: 7552558].
18 Sytema S, Wunderink L, Bloemers W, et al. Assertive community treatment in the Netherlands: a randomized controlled trial. Acta Psychiatr Scand. Aug. 2007;116(2):105-12. Epub: 2007/07/26. [pmid: 17650271].
19 Bond GR, Pensec M, Dietzen L, et al. Intensive case management for frequent users of psychiatric hospitals in a large city: A comparison of team and individual caseloads. Psychosoc Rehab J. 1991;15(1):90-8.
20 Hamernik E, Pakenham KI. Assertive community treatment for persons with severe mental disorders: A controlled treatment outcome study. Behaviour Change. 1999;16(4):259-68.
21 Liem SK, Lee CC. Effectiveness of assertive community treatment in Hong Kong among patients with frequent hospital admissions. Psychiatr Serv. Nov. 1. 2013;64(11):1170-2. Epub: 2013/11/05. [pmid: 24185540].
22 Dincin J, Wasmer D, Witheridge TF, et al. Impact of assertive community treatment on the use of state hospital inpatient bed-days. Hosp Community Psychiatry. Sep. 1993;44(9):833-8. Epub: 1993/09/01. [pmid: 8225294].
23 Tibbo P, Chue P, Wright E. Hospital outcome measures following assertive community treatment in Edmonton, Alberta. Can J Psychiatry. Apr. 1999;44(3):276-9. Epub: 1999/05/04. [pmid: 10225130].
24 Udechuku A, Olver J, Hallam K, et al. Assertive community treatment of the mentally ill: service model and effectiveness (Structured abstract). Australasian Psychiatry. 2005;13(2):129-34. [pmid: 15948908].
25 Dietzen LL, Bond GR. Relationship between case manager contact and outcome for frequently hospitalized psychiatric clients. Hosp Community Psychiatry. Sep. 1993;44(9):839-43. Epub: 1993/09/01. [pmid: 8225295].
26 Burns T, Rugkasa J, Molodynski A, et al. Community treatment orders for patients with psychosis (OCTET): a randomised controlled trial. Lancet. May. 11. 2013;381(9878):1627-33. Epub: 2013/03/30. [pmid: 23537605].
27 Steadman HJ, Gounis K, Dennis D, et al. Assessing the New York City involuntary outpatient commitment pilot program. Psychiatr Serv. Mar. 2001;52(3):330-6. Epub: 2001/03/10. [pmid: 11239100].
28 Swartz MS, Swanson JW, Wagner HR, et al. Can involuntary outpatient commitment reduce hospital recidivism?: Findings from a randomized trial with severely mentally ill individuals. Am J Psychiatry. Dec. 1999;156(12):1968-75. Epub: 1999/12/10. [pmid: 10588412].
29 Compton SN, Swanson JW, Wagner HR, et al. Involuntary outpatient commitment and homelessness in persons with severe mental illness. Ment Health Serv Res. Mar. 2003;5(1):27-38. Epub: 2003/02/27. [pmid: 12602644].
30 Segal SP, Burgess PM. Conditional release: a less restrictive alternative to hospitalization?. Psychiatr Serv. Nov. 2006;57(11):1600-6. Epub: 2006/11/07. [pmid: 17085608].
31 Segal SP, Burgess PM. Factors in the selection of patients for conditional release from their first psychiatric hospitalization. Psychiatr Serv. Nov. 2006;57(11):1614-22. Epub: 2006/11/07. [pmid: 17085610].
32 Segal SP, Burgess PM. Use of community treatment orders to prevent psychiatric hospitalization. Aust N Z J Psychiatry. Aug. 2008;42(8):732-9. Epub: 2008/07/16. [pmid: 18622781].
33 Segal SP, Burgess PM. The utility of extended outpatient civil commitment. Int J Law Psychiatry. Nov-Dec. 2006;29(6):525-34. Epub: 2006/10/31. [pmid: 17070577].
34 Swartz MS, Wilder CM, Swanson JW, et al. Assessing outcomes for consumers in New York's assisted outpatient treatment program. Psychiatr Serv. Oct. 2010;61(10):976-81. Epub: 2010/10/05. [pmid: 20889634].
35 Vaughan K, McConaghy N, Wolf C, et al. Community treatment orders: relationship to clinical care, medication compliance, behavioural disturbance and readmission. Aust N Z J Psychiatry. Oct. 2000;34(5):801-8. Epub: 2000/10/19. [pmid: 11037366].
36 Geller J, Grudzinskas AJ Jr, McDermeit M, et al. The efficacy of involuntary outpatient treatment in Massachusetts. Adm Policy Ment Health. Jan. 1998;25(3):271-85. Epub: 1998/09/04. [pmid: 9727222].
37 Kisely S, Preston N, Xiao J, et al. An eleven-year evaluation of the effect of community treatment orders on changes in mental health service use. J Psychiatr Res. May. 2013;47(5):650-6. Epub: 2013/02/19. [pmid: 23415453].
38 Segal SP, Burgess P. Extended outpatient civil commitment and treatment utilization. Soc Work Health Care. 2006;43(2-3):37-51. Epub: 2006/09/08. [pmid: 16956852].
39 Christy A, Petrila J, McCranie M, et al. Involuntary outpatient commitment in florida: case information and provider experience and opinions. Int J Forensic Ment Health. 2009;8(2):122-30.
40 Fernandez GA, Nygard S. Impact of involuntary outpatient commitment on the revolving-door syndrome in North Carolina. Hosp Community Psychiatry. Sep. 1990;41(9):1001-4. Epub: 1990/09/01. [pmid: 2210692].
41 Greenberg D, Mazar J, Brom D, et al. Involuntary outpatient commitment: a naturalistic study of its use and a consumer survey at one community mental health center in Israel. Med Law. Mar. 2005;24(1):95-110. Epub: 2005/05/13. [pmid: 15887616].
42 Kallapiran K, Sankaranarayanan A, Lewin T. A pilot investigation of the relationship between community treatment orders and hospital utilization rates. Australas Psychiatry. Dec. 2010;18(6):503-5. Epub: 2010/12/02. [pmid: 21117836].
43 Munetz MR, Grande T, Kleist J, et al. The effectiveness of outpatient civil commitment. Psychiatr Serv. Nov. 1996;47(11):1251-3. Epub: 1996/11/01. [pmid: 8916245].
44 Nakhost A, Perry JC, Frank D. Assessing the outcome of compulsory treatment orders on management of psychiatric patients at 2 McGill University-associated hospitals. Can J Psychiatry. Jun. 2012;57(6):359-65. Epub: 2012/06/12. [pmid: 22682573].
45 O'Brien AM, Farrell SJ. Community treatment orders: profile of a Canadian experience. Canadian Journal of Psychiatry. Revue Canadienne de Psychiatrie. Jan. 2005;50(1):27-30. Epub: 2005/03/10. [pmid: 15754662].
46 Rohland BM. The role of outpatient commitment in the management of persons with schizophrenia. Iowa Consortium for Mental Health. Des Moines, IA. 1998.
47 Zanni GR, Stavis PF. The effectiveness and ethical justification of psychiatric outpatient commitment. Am J Bioeth. Nov. 2007;7(11):31-41. Epub: 2007/11/21. [pmid: 18027299].
48 Elbogen EB, Swanson JW, Swartz MS. Effects of legal mechanisms on perceived coercion and treatment adherence among persons with severe mental illness. J Nerv Ment Dis. Oct. 2003;191(10):629-37. Epub: 2003/10/14. [pmid: 14555864].
49 Swanson JW, Borum R, Swartz MS, et al. Can involuntary outpatient commitment reduce arrests among persons with severe mental illness?. Criminal Justice and Behavior. Apr 2001. 2001;28(2):156-89.
50 Burns T, Creed F, Fahy T, et al. Intensive versus standard case management for severe psychotic illness: a randomised trial. UK 700 Group. Lancet. Jun. 26. 1999;353(9171):2185-9. Epub: 1999/07/07. [pmid: 10392982].
51 Tyrer P, Hassiotis A, Ukoumunne O, et al. Intensive case management for psychotic patients with borderline intelligence. UK 700 Group. Lancet. Sep. 18. 1999;354(9183):999-1000. Epub: 1999/09/29. [pmid: 10501366].
52 Bush CT, Langford MW, Rosen P, et al. Operation outreach: intensive case management for severely psychiatrically disabled adults. Hosp Community Psychiatry. Jun. 1990;41(6):647-9. discussion 9-51. Epub: 1990/06/01. [pmid: 2361668].
53 Chan S, Mackenzie A, Jacobs P. Cost-effectiveness analysis of case management versus a routine community care organization for patients with chronic schizophrenia (Structured abstract). Arch Psychiatr Nurs. 2000;14(2):98-104. [pmid: 10783528].
54 Harrison-Read P, Lucas B, Tyrer P, et al. Heavy users of acute psychiatric beds: randomized controlled trial of enhanced community management in an outer London borough. Psychol Med. Apr. 2002;32(3):403-16. Epub: 2002/05/07. [pmid: 11989986].
55 Lichtenberg P, Levinson D, Sharshevsky Y, et al. Clinical case management of revolving door patients - a semi-randomized study. Acta Psychiatr Scand. Jun. 2008;117(6):449-54. Epub: 2008/03/12. [pmid: 18331577].
56 Muijen M, Cooney M, Strathdee G, et al. Community psychiatric nurse teams: intensive support versus generic care. Br J Psychiatry. Aug. 1994;165(2):211-7. Epub: 1994/08/01. [pmid: 7953034].
57 Quinlivan R, Hough R, Crowell A, et al. Service utilization and costs of care for severely mentally ill clients in an intensive case management program. Psychiatr Serv. Apr. 1995;46(4):365-71. Epub: 1995/04/01. [pmid: 7788458].
58 Schmidt LT, Gill KJ, Pratt CW, et al. Comparison of Service Outcomes of Case Management Teams With and Without a Consumer Provider. Am J Psychiatr Rehab. 2008/10/13. 2008;11(4):310-29.
59 Hornstra RK, Bruce-Wolfe V, Sagduyu K, et al. The effect of intensive case management on hospitalization of patients with schizophrenia. Hosp Community Psychiatry. Sep. 1993;44(9):844-7. Epub: 1993/09/01. [pmid: 8225296].
60 Kolbasovsky A. Reducing 30-day inpatient psychiatric recidivism and associated costs through intensive case management. Prof Case Manag. Mar-Apr. 2009;14(2):96-105. Epub: 2009/03/26. [pmid: 19318901].
61 Kolbasovsky A, Reich L, Futterman R. Predicting future hospital utilization for mental health conditions. J Behav Health Serv Res. Jan. 2007;34(1):34-42. Epub: 2006/12/13. [pmid: 17160724].
62 Kolbasovsky A, Reich L, Meyerkopf N. Reducing six-month inpatient psychiatric recidivism and costs through case management. Care Manag J. 2010;11(1):2-10. Epub: 2010/04/30. [pmid: 20426315].
63 Parson C. Managed care. The effect of case management on state psychiatric clients. J Psychosoc Nurs Ment Health Serv. Oct. 1999;37(10):16-21. Epub: 1999/10/26. [pmid: 10529959].
64 Preston NJ, Fazio S. Establishing the efficacy and cost effectiveness of community intensive case management of long-term mentally ill: a matched control group study. Aust N Z J Psychiatry. Feb. 2000;34(1):114-21. Epub: 2001/02/24. [pmid: 11185923].
65 Rothbard AB, Chhatre S, Zubritsky C, et al. Effectiveness of a high end users program for persons with psychiatric disorders. Community Ment Health J. Oct. 2012;48(5):598-603. Epub: 2012/02/01. [pmid: 22290303].
66 Husted J, Wentler S, Allen G, et al. The effectiveness of community support programs in rural Minnesota: A ten year longitudinal study. Psychiatr Rehab J. 2000 Sum. 2000;24(1):69-72.
67 Mahendran R, Hendriks M, Thambyrajah V, et al. Case Management in a Psychiatric Hospital: Review of Outcomes and Resource Utilisation. Hong Kong J Psychiatr. 2006;16(1):3-6.
68 McFarlane WR, Link B, Dushay R, et al. Psychoeducational multiple family groups: four-year relapse outcome in schizophrenia. Fam Process. Jun. 1995;34(2):127-44. Epub: 1995/06/01. [pmid: 7589414].
69 Pitschel-Walz G, Bauml J, Bender W, et al. Psychoeducation and compliance in the treatment of schizophrenia: results of the Munich Psychosis Information Project Study. J Clin Psychiatry. Mar. 2006;67(3):443-52. Epub: 2006/05/03. [pmid: 16649832].
70 Bauml J, Pitschel-Walz G, Volz A, et al. Psychoeducation in schizophrenia: 7-year follow-up concerning rehospitalization and days in hospital in the Munich Psychosis Information Project Study. J Clin Psychiatry. Jun. 2007;68(6):854-61. Epub: 2007/06/27. [pmid: 17592908].
71 de Groot L, Lloyd C, King R. An evaluation of a family psychoeducation program in community mental health. Psychiatr Rehabil J. Summer. 2003;27(1):18-23. Epub: 2003/09/12. [pmid: 12967228].
72 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: Part II. Impact on clinical outcome, function, and costs. Psychiatr Serv. Jul. 2006;57(7):937-45. Epub: 2006/07/04. [pmid: 16816277].
73 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: part I. Intervention and implementation in a randomized effectiveness trial. Psychiatr Serv. Jul. 2006;57(7):927-36. Epub: 2006/07/04. [pmid: 16816276].
74 Bauer MS. The collaborative practice model for bipolar disorder: design and implementation in a multi-site randomized controlled trial. Bipolar Disord. Oct. 2001;3(5):233-44. Epub: 2002/03/21. [pmid: 11903206].
75 Lay B, Blank C, Lengler S, et al. Preventing compulsory admission to psychiatric inpatient care using psycho-education and monitoring: feasibility and outcomes after 12 months. Eur Arch Psychiatry Clin Neurosci. 2014. Nov. 1. Epub: 2014/11/02. [pmid: 25361537].
76 Sledge WH, Lawless M, Sells D, et al. Effectiveness of peer support in reducing readmissions of persons with multiple psychiatric hospitalizations. Psychiatr Serv. May. 2011;62(5):541-4. Epub: 2011/05/03. [pmid: 21532082].
77 Prince JD. Practices preventing rehospitalization of individuals with schizophrenia. J Nerv Ment Dis. Jun. 2006;194(6):397-403. Epub: 2006/06/15. [pmid: 16772855].