# Potentially Relevant Ongoing and Unpublished Studies

Table D1 Ongoing studies

Study Name Location Trial Identifier | Sponsors and Collaborators Study Status | Population Disease/Condition Age | Interventions / Groups | Primary Outcome Measures
Peer support for schizophrenia Location NR CD010880 | Cochrane Schizophrenia Group Ongoing, publication date NR | Majority of patients in included studies required to:; - Be adults; - Have diagnosis of schizophrenia, schizophrenia-like disorders, bipolar disorder, or serious affective disorders | Long-term approach for reducing readmissions in high-risk individuals: Community-based peer support interventions Comparators:; - Other psychosocial or supportive intervention not involving a “peer” individual or group; - Standard care | - Hospital admission; - Time to hospitalization; - Use of specialist community services (i.e., early interventions, assertive outreach and crisis teams); - Relapse; - Time to relapse
Effectiveness and Cost Effectiveness of Peer Mentors in Reducing Hospital Use Connecticut, US NCT01566513 | NIMH Ongoing, publication date NR | - Aged 18 years or older; - ≥2 psychiatric hospitalizations in the past year; - Diagnosis of SMI | Long-term approaches for reducing readmissions in high-risk individuals:; - Community-based peer support interventions delivered by peer case managers; - Community-based peer support interventions delivered by non-peer recovery mentors; Comparator: Standard care | - Service use
S22-01 - Preventive monitoring of psychiatric patients at risk for compulsory readmission: preliminary results of a multi-center RCT Mannheim, Germany Study identifier NR | Sponsors NR Ongoing; preliminary results available, but final analyses and publication unavailable | - Aged 18-65 years; - Psychiatric inpatients with schizophrenia or affective disorder | Transitional support service: Comprehensive psychoeducational program consisting of: (1) Focus on warning signs; (2) Distribution of crisis cards; (3) 24-month preventive monitoring of patients’ mental health status and health care use Comparator: Standard care | - Psychiatric symptoms; - Risk for violence; - Treatment satisfaction; - Empowerment; - Quality of life; - Health care use
P-601 - Understanding the revolving door syndrome Coimbra, Portugal Study identifier NR | Sponsors NR Ongoing; preliminary results, but final analyses and publication both unavailable | - Patients with high number of admissions to Coimbra University Hospitals | Social network and clinical service use, but specific types being evaluated NR | - Hospital readmission
Goal setting and activities to enhance goal pursuit for adults with acquired disabilities participating in rehabilitation Location NR CD009727 | Cochrane Consumers and Communication Group Ongoing, publication date NR | - People receiving rehabilitation for disability acquired in adulthood (i.e., after 16 years of age); - Presence of cognitive or psychiatric impairments in study populations will comprise subgroup analysis if enough evidence available | Long-term approaches for reducing readmissions in high-risk individuals:; - Goal setting interventions; - Interventions to enhance goal pursuit; - One approach to goal setting and/or activities to enhance goal pursuit; Comparators:; - No goal setting; - No additional activities to enhance goal pursuit; - Other approaches to goal setting and/or activities to enhance goal pursuit | - Health-related quality of life; - Activity outcomes (e.g., activities of daily living, mobility); - Participation outcomes (e.g., work, community integration, social relationships)
Enhanced crisis planning for serious mental illness Location NR CD009482 | Cochrane Schizophrenia Group Ongoing, publication date NR | - Adults between 18 and 65 years; - Diagnosed with schizophrenia, schizophrenia-like disorders, bipolar disorder, or depressive disorders using any criteria; - Any length of illness and treatment setting eligible | Long-term approach for reducing readmission: Crisis planning interventions (any type meant primarily to prevent relapse and hospital readmission) Comparator: Standard care | - Hospital readmission, relapse of mental illness, or both
P02-292 - A randomized controlled trial on the efficacy of group psychoeducation family intervention for carers of persons with schizophrenia in Shanghai Shanghai Changning Mental Health Center, Shanghai Jiao Tong University, Shanghai, China Trial identifier NR | Sponsors NR Study status NR | - Patients with schizophrenia and their relatives | Long-term approach for reducing readmissions in high-risk individuals: Community-based, group psychoeducational family intervention Comparator: Control group, details of care received NR | - Hospital readmission; - Knowledge related to mental illness; - Family attitudes toward patient; - Overall (not specified); - Treatment compliance; - Rate of relapse; - Overall functioning; - Marital role; - Care of self; - Negative influence on society
27.5. The impact of community treatment orders on patients with assertive community treatment and without Ottawa, Canada Study identifier NR | Sponsors NR Preliminary findings available, but study status NR and manuscript unavailable | - Patients with “the highest intensity of community based service available prior to a CTO being considered”; - Population characteristics NR | Long-term approach for reducing readmissions in high-risk individuals: CTO in combination with ACT Comparator: CTO without ACT | - Hospital bed days; - Diagnosis; - Concurrent substance abuse; - Criminal justice encounters

ACT = assertive community treatment; CTO = community treatment orders; NIMH = National Institutes of Mental Health; NR = not reported; RCT = randomized controlled trial; SMI = serious mental illness; US = United States

Table D2 Unpublished study

Study Name Location Trial Identifier | Sponsors and Collaborators Study Status | Population Disease/Condition Age | Interventions / Groups | Primary Outcome Measures
P-1177 - “Porta aberta” - a psychoeducational programme for bipolar disorders’ patients Amadora, Portugal Study identifier NR | Sponsors NR Completed, but manuscript unavailable | - Patients with bipolar disorder discharged from inpatient psychiatric hospital; - Age eligibility NR, but mean age 37.3 | Transition support service: Group psychoeducation program called “Porta Aberta” (Open Door) based in a day hospital Comparator: Single-group pre-post comparison | - Hospital readmission; - Average LOS during readmission

LOS = length of stay; NR = not reported