# Excluded Studies

Exclusion Codes
- X1 = Ineligible Publication Type or Wrong Language
- X2 = Ineligible Population(s)
- X3 = Ineligible/No Intervention(s)
- X4 = Ineligible Setting(s)
- X5 = Does not answer any GQ
- X6 = Ineligible Study Design
- X7 = Ineligible/No Comparator(s)
- X8 = Irretrievable – only abstract available

1 Nursing Interventions to Improve Functional Outcome in Patients with Severe Mental Illness (NISMI). Exclusion Code: X2.
2 Comprehensive aftercare service for patients with severe mental illnesses. Exclusion Code: X2.
3 Recovery Guide Intervention for Recurrent Psychiatric Hospitalization. Exclusion Code: X1.
4 Supported discharge vs In-patient Treatment Evaluation (SITE). Exclusion Code: X2.
5 Longer stays, MH care lower SA readmissions. Mental Health Weekly. 1995;5(4):4. Exclusion Code: X1.
6 Home setting offers alternative for clients in crisis. Mental Health Weekly. 1996;6(22):1. Exclusion Code: X1.
7 The rise in emergency admissions project. Executive summary (Structured abstract). Database of Abstracts of Reviews of Effects. Coventry University, Coventry Business School. York. 1998:p. 1ff. Exclusion Code: X2.
8 Gold Award: the Wellspring of the clubhouse model for social and vocational adjustment of persons with serious mental illness. Psychiatr Serv. Nov. 1999;50(11):1473-6. Exclusion Code: X2. [pmid: 10543858].
9 No benefit or harm in treatment orders. Community Care. 2007;(1664):10. Exclusion Code: X1. [pmid: 24693567].
10 Aberg-Wistedt A, Cressell T, Lidberg Y, et al. Two-year outcome of team-based intensive case management for patients with schizophrenia. Psychiatr Serv. Dec. 1995;46(12):1263-6. Exclusion Code: X2. [pmid: 8590112].
11 Adams CL, El-Mallakh RS. Patient outcome after treatment in a community-based crisis stabilization unit. J Behav Health Serv Res. Jul. 2009;36(3):396-9. Exclusion Code: X2. [pmid: 18766444].
12 Adams P, Nielson H. Evidence based practice: decreasing psychiatric revisits to the emergency department. Issues Ment Health Nurs. Aug. 2012;33(8):536-43. Exclusion Code: X2. [pmid: 22849781].
13 Addington DE, McKenzie E, Wang J. Validity of hospital admission as an outcome measure of services for first-episode psychosis. Psychiatr Serv. Mar. 2012;63(3):280-2. Exclusion Code: X2. [pmid: 22267251].
14 Adesanya A. Impact of a crisis assessment and treatment service on admissions into an acute psychiatric unit. Australas Psychiatry. Jun. 2005;13(2):135-9. Exclusion Code: X2. [pmid: 15948909].
15 Audini B, Marks IM, Lawrence RE, et al. Home-based versus out-patient/in-patient care for people with serious mental illness. Phase II of a controlled study. Br J Psychiatry. Aug. 1994;165(2):204-10. Exclusion Code: X2. [pmid: 7953033].
16 Banerjee S, O'Neill-Byrne K, Exworthy T, et al. The Belmarsh Scheme. A prospective study of the transfer of mentally disordered remand prisoners from prison to psychiatric units. Br J Psychiatry. Jun. 1995;166(6):802-5. Exclusion Code: X2. [pmid: 7663832].
17 Baron K, Hays JR. Characteristics of readmitted psychiatric inpatients. Psychol Rep. Aug. 2003;93(1):235-8. Exclusion Code: X3. [pmid: 14563056].
18 Barr R. Psychiatric follow-up for ex-prisoners. Aust N Z J Psychiatry. Mar. 1991;25(1):3. 9. Exclusion Code: X2. [pmid: 1646594].
19 Bartak A, Andrea H, Spreeuwenberg MD, et al. Patients with cluster a personality disorders in psychotherapy: an effectiveness study. Psychother Psychosom. 2011;80(2):88-99. Exclusion Code: X2. [pmid: 21196806].
20 Basan A, Pitschel-Walz G, Bäuml J. Psychoeducational intervention for schizophrenic patients and subsequent long-term ambulatory care. A four-year follow-up. Fortschr Neurol Psychiatr. 2000:537-45. Exclusion Code: X1. [pmid: 11200857].
21 Bauer S, Wolf M, Haug S, et al. The effectiveness of internet chat groups in relapse prevention after inpatient psychotherapy. Psychother Res. Mar. 2011;21(2):219-26. Exclusion Code: X2. [pmid: 21347978].
22 Beebe LH. Community nursing support for clients with schizophrenia. Arch Psychiatr Nurs. Oct. 2001;15(5):214-22. Exclusion Code: X2. [pmid: 11584350].
23 Beecham J, Knapp M, McGilloway S, et al. Leaving hospital II: the cost-effectiveness of community care for former long-stay psychiatric hospital patients (Structured abstract). Journal of Mental Health. 1996:379-94. Exclusion Code: X2.
24 Behr GM, Christie C, Soderlund N, et al. Patterns and determinants of acute psychiatric readmissions. S Afr Med J. May. 2002;92(5):369-74. Exclusion Code: X2. [pmid: 12108169].
25 Bell MD, Lysaker PH, Milstein RM. Clinical benefits of paid work activity in schizophrenia. Schizophr Bull. 1996;22(1):51-67. Exclusion Code: X3. [pmid: 8685664].
26 Ben-Arie O, Koch A, Welman M, et al. The effect of research on readmission to a psychiatric hospital. Br J Psychiatry. Jan. 1990;156:37-9. Exclusion Code: X2. [pmid: 2297618].
27 Bennewith O, Evans J, Donovan J, et al. A contact-based intervention for people recently discharged from inpatient psychiatric care: a pilot study. Arch Suicide Res. 2014;18(2):131-43. Exclusion Code: X2. [pmid: 24673299].
28 Bertman-Pate LJ, Burnett DM, Thompson JW, et al. The New Orleans Forensic Aftercare Clinic: a seven year review of hospital discharged and jail diverted clients. Behav Sci Law. 2004;22(1):159-69. Exclusion Code: X2. [pmid: 14963885].
29 Bittle RG. Acute care treatment services (ACTS): a model program for providing acute psychiatric services in a homelike environment in an institutional setting. Behavioral Residential Treatment. 1986;1(4):275-88. Exclusion Code: X2. [pmid: 12208982].
30 Blacklock E. Home clinic programme: an alternative model for private mental health facilities and sufferers of major depression. Int J Ment Health Nurs. Mar. 2006;15(1):3-9. Exclusion Code: X2. [pmid: 16499785].
31 Boardman AP, Hodgson RE, Lewis M, et al. North Staffordshire Community Beds Study: longitudinal evaluation of psychiatric in-patient units attached to community mental health centres. I: Methods, outcome and patient satisfaction. Br J Psychiatry. Jul. 1999;175:70-8. Exclusion Code: X2. [pmid: 10621771].
32 Boaz TL, Becker MA, Andel R, et al. Risk factors for early readmission to acute care for persons with schizophrenia taking antipsychotic medications. Psychiatr Serv. Dec. 1. 2013;64(12):1225-9. Exclusion Code: X2. [pmid: 23945797].
33 Boden R, Brandt L, Kieler H, et al. Early non-adherence to medication and other risk factors for rehospitalization in schizophrenia and schizoaffective disorder. Schizophr Res. Dec. 2011;133(1-3):36-41. Exclusion Code: X3. [pmid: 21982098].
34 Bond GR, McDonel EC, Miller LD, et al. Assertive community treatment and reference groups: An evaluation of their effectiveness for young adults with serious mental illness and substance abuse problems. Psychosoc Rehab J. 1991;15(2):31-43. PsycARTICLES Identifier: prj-15-2-31. First Author & Affiliation: Bond, Gary R. Exclusion Code: X2.
35 Bordbar MRF, Soltanifar A, Talaei A. Short-term family-focused psycho-educational program for bipolar mood disorder in Mashhad. Iranian Journal of Medical Sciences. 2009:104-9. Exclusion Code: X2.
36 Borum R, Swartz M, Riley S, et al. Consumer perceptions of involuntary outpatient commitment. Psychiatr Serv. Nov. 1999;50(11):1489-91. Exclusion Code: X2. [pmid: 10543860].
37 Bota RG, Munro JS, Sagduyu K. Benefits of boarding home placement in patients with schizophrenia. South Med J. Feb. 2007;100(2):145-8. Exclusion Code: X2. [pmid: 17330683].
38 Bracke P, Christiaens W, Verhaeghe M. Self-esteem, self-efficacy, and the balance of peer support among persons with chronic mental health problems. J Appl Soc Psychol. 2008;38(2):436-59. Exclusion Code: X2.
39 Brahams D. "Treatability" and discharge of psychopaths. Lancet. Apr. 2. 1994;343(8901):847. Exclusion Code: X3. [pmid: 7908086].
40 Burgess P, Bindman J, Leese M, et al. Do community treatment orders for mental illness reduce readmission to hospital? An epidemiological study. Soc Psychiatry Psychiatr Epidemiol. Jul. 2006;41(7):574-9. Exclusion Code: X2. [pmid: 16685479].
41 Burnam MA, Morton SC, McGlynn EA, et al. An experimental evaluation of residential and nonresidential treatment for dually diagnosed homeless adults. J Addict Dis. 1995;14(4):111-34. Exclusion Code: X2. [pmid: 8929936].
42 Burns T. Letter in response to Dr Segal's commentary. Evid Based Ment Health. Nov. 2013;16(4):117. Exclusion Code: X1. [pmid: 24104556].
43 Burns T, Beadsmoore A, Bhat AV, et al. A controlled trial of home-based acute psychiatric services. I: Clinical and social outcome. Br J Psychiatry. Jul. 1993;163:49-54. Exclusion Code: X2. [pmid: 8353699].
44 Burns T, Raftery J. Cost of schizophrenia in a randomized trial of home-based treatment. Schizophr Bull. 1991;17(3):407-10. Exclusion Code: X2. [pmid: 1947865].
45 Burns T, Raftery J, Beadsmoore A, et al. A controlled trial of home-based acute psychiatric services. II: Treatment patterns and costs. Br J Psychiatry. Jul. 1993;163:55-61. Exclusion Code: X2. [pmid: 8353700].
46 Busch AB, Wilder CM, Van Dorn RA, et al. Changes in guideline-recommended medication possession after implementing Kendra's law in New York. Psychiatr Serv. Oct. 2010;61(10):1000-5. Exclusion Code: X3. [pmid: 20889638].
47 Byford S, Sharac J, Lloyd-Evans B, et al. Alternatives to standard acute in-patient care in England: readmissions, service use and cost after discharge. Br J Psychiatry Suppl. Aug. 2010;53:s20-5. Exclusion Code: X2. [pmid: 20679275].
48 Byrne SL, Hooke GR, Newnham EA, et al. The effects of progress monitoring on subsequent readmission to psychiatric care: a six-month follow-up. J Affect Disord. Mar. 2012;137(1-3):113-6. Exclusion Code: X3. [pmid: 22244373].
49 Callaghan P, Eales S, Coates T, et al. A review of research on the structure, process and outcome of liaison mental health services (Structured abstract). J Psychiatr Ment Health Nurs. 2003:155-65. Exclusion Code: X2. [pmid: 12662332].
50 Carr VJ, Lewin TJ, Sly KA, et al. Adverse incidents in acute psychiatric inpatient units: rates, correlates and pressures. Aust N Z J Psychiatry. Apr. 2008;42(4):267-82. Exclusion Code: X2. [pmid: 18330769].
51 Carreteiro G, Xavier S, Klut C, et al. P-1177 - “Porta aberta” - a psychoeducational programme for bipolar disorders’ patients. Eur Psychiatry. 2012;27:1. Exclusion Code: X1. [pmid: 22153731].
52 Cassidy E, Hill S, O'Callaghan E. Efficacy of a psychoeducational intervention in improving relatives' knowledge about schizophrenia and reducing rehospitalisation. Eur Psychiatry. Dec. 2001;16(8):446-50. Exclusion Code: X2. [pmid: 11777734].
53 Catty JS, Bunstead Z, Burns T, et al. Day centres for severe mental illness. Cochrane Database Syst Rev. 2007;(1):CD001710. Exclusion Code: X2. [pmid: 17253463].
54 Cauchi R, Landess S, Thangasamy A. State Laws Mandating or Regulating Mental Health Benefits. Denver, CO. National Conference of State Legislatures. 2014. http://www.ncsl.org/research/health/mental-health-benefits-state-mandates.aspx. 12 Sept. Exclusion Code: X5.
55 Chadda RK, Amarjeet, Jain A, et al. Family rehabilitation of psychiatric patients: a study of course of involuntary admissions to a psychiatric hospital. Int J Rehabil Res. Dec. 2000;23(4):327-30. Exclusion Code: X2. [pmid: 11192570].
56 Chan SWC, Li Z, Klainin-Yobas P, et al. Effectiveness of a peer-led self-management programme for people with schizophrenia: protocol for a randomized controlled trial. J Adv Nurs. 2014;70(6):1425-35. Exclusion Code: X1. [pmid: 24224787].
57 Chandler D, Meisel J, Hu TW, et al. Client outcomes in a three-year controlled study of an integrated service agency model. Psychiatr Serv. Dec. 1996;47(12):1337-43. Exclusion Code: X2. [pmid: 9117472].
58 Chang G, Weiss A, Kosowsky JM, et al. Characteristics of adult psychiatric patients with stays of 24 hours or more in the emergency department. Psychiatr Serv. Mar. 2012;63(3):283-6. Exclusion Code: X5. [pmid: 22267250].
59 Chien WT, Chan SW. One-year follow-up of a multiple-family-group intervention for Chinese families of patients with schizophrenia. Psychiatr Serv. Nov. 2004;55(11):1276-84. Exclusion Code: X2. [pmid: 15534017].
60 Chien WT, Thompson DR. An RCT with three-year follow-up of peer support groups for Chinese families of persons with schizophrenia. Psychiatric services (Washington, D.C.). 2013:997-1005. Exclusion Code: X2.
61 Chinman M, George P, Dougherty RH, et al. Peer support services for individuals with serious mental illnesses: assessing the evidence. Psychiatr Serv. Apr. 1. 2014;65(4):429-41. Exclusion Code: X2. [pmid: 24549400].
62 Chinman MJ, Rosenheck R, Lam JA, et al. Comparing consumer and nonconsumer provided case management services for homeless persons with serious mental illness. J Nerv Ment Dis. Jul. 2000;188(7):446-53. Exclusion Code: X2. [pmid: 10919704].
63 Chinman MJ, Weingarten R, Stayner D, et al. Chronicity reconsidered: improving person-environment fit through a consumer-run service. Community Ment Health J. Jun. 2001;37(3):215-29. Exclusion Code: X2. [pmid: 11440423].
64 Chiverton P, Tortoretti D, LaForest M, et al. Bridging the gap between psychiatric hospitalization and community care: cost and quality outcomes (Structured abstract). J Am Psychiatr Nurses Assoc. 1999:46-53. Exclusion Code: X2.
65 Christensen AB. Community psychiatric treatment and needs of admission of psychiatric patients. A controlled study 5 years after introduction of a community psychiatric center. Ugeskr Laeger. 1997:2702-10. Exclusion Code: X1. [pmid: 9173635].
66 Christensen AB, Rasmussen EM, Brødsgaard MA, et al. In-hospital day for patients connected with the District Psychiatric Center in Svendborg. A controlled study. Ugeskr Laeger. 1992:1703-8. Exclusion Code: X1. [pmid: 1632006].
67 Christensen RC. Involuntary hospitalization or aversive incarceration?. Psychiatr Serv. May. 2000;51(5):676-7. Exclusion Code: X2. [pmid: 10783194].
68 Clarke GN, Herinckx HA, Kinney RF, et al. Psychiatric hospitalizations, arrests, emergency room visits, and homelessness of clients with serious and persistent mental illness: Findings from a randomized trial of two ACT programs vs. usual care. Mental Health Services Research. 2000;2(3):155-64. Exclusion Code: X2. [pmid: 11256724].
69 Clarke T, Baker P, Watts CJ, et al. Self-harm in adults: A randomised controlled trial of nurse-led case management versus routine care only. Journal of mental health (Abingdon, England). 2002:167-76. Exclusion Code: X2.
70 Cohen LJ, Test MA, Brown RL. Suicide and schizophrenia: data from a prospective community treatment study. Am J Psychiatry. May. 1990;147(5):602-7. Exclusion Code: X2. [pmid: 2327487].
71 Conte G, Ferrari R, Guarneri L, et al. Reducing the "revolving door" phenomenon. Am J Psychiatry. Nov. 1996;153(11):1512. Exclusion Code: X5. [pmid: 8890701].
72 Cook JA, Copeland ME, Corey L, et al. Developing the evidence base for peer-led services: changes among participants following Wellness Recovery Action Planning (WRAP) education in two statewide initiatives. Psychiatr Rehabil J. Autumn. 2010;34(2):113-20. Exclusion Code: X2. [pmid: 20952364].
73 Cook JA, Copeland ME, Floyd CB, et al. A randomized controlled trial of effects of Wellness Recovery Action Planning on depression, anxiety, and recovery. Psychiatr Serv. Jun. 2012;63(6):541-7. Exclusion Code: X2. [pmid: 22508435].
74 Cook JA, Copeland ME, Hamilton MM, et al. Initial outcomes of a mental illness self-management program based on wellness recovery action planning. Psychiatr Serv. Feb. 2009;60(2):246-9. Exclusion Code: X2. [pmid: 19176420].
75 Cook JA, Copeland ME, Jonikas JA, et al. Results of a randomized controlled trial of mental illness self-management using Wellness Recovery Action Planning. Schizophr Bull. Jun. 2012;38(4):881-91. Exclusion Code: X2. [pmid: 21402724].
76 Cosden M, Ellens JK, Schnell JL, et al. Evaluation of a mental health treatment court with assertive community treatment. Behav Sci Law. 2003;21(4):415-27. Exclusion Code: X2. [pmid: 12898500].
77 Craig TJ, Bracken J. A case-control study of rapid readmission in a state hospital population. Ann Clin Psychiatry. Jun. 1995;7(2):79-85. Exclusion Code: X2. [pmid: 8556097].
78 Creed F, Black D, Anthony P, et al. Randomised controlled trial of day patient versus inpatient psychiatric treatment. BMJ. Apr. 21. 1990;300(6731):1033-7. Exclusion Code: X2. [pmid: 2188696].
79 Creed F, Mbaya P, Lancashire S, et al. Cost effectiveness of day and inpatient psychiatric treatment: results of a randomised controlled trial. BMJ. May. 10. 1997;314(7091):1381-5. Exclusion Code: X2. [pmid: 9161310].
80 Cuddeback GS, Morrissey JP, Domino ME, et al. Fidelity to recovery-oriented ACT practices and consumer outcomes. Psychiatr Serv. Apr. 1. 2013;64(4):318-23. Exclusion Code: X2. [pmid: 23318948].
81 Cuffel BJ, Held M, Goldman W. Predictive models and the effectiveness of strategies for improving outpatient follow-up under managed care. Psychiatr Serv. Nov. 2002;53(11):1438-43. Exclusion Code: X2. [pmid: 12407272].
82 Curtis JL, Millman EJ, Struening E, et al. Effect of case management on rehospitalization and utilization of ambulatory care services. Hosp Community Psychiatry. Sep. 1992;43(9):895-9. Exclusion Code: X2. [pmid: 1330871].
83 Curtis JL, Millman EJ, Struening E, et al. Deaths among former psychiatric inpatients in an outreach case management program. Psychiatr Serv. Apr. 1996;47(4):398-402. Exclusion Code: X5. [pmid: 8689371].
84 Curtis JL, Millman EJ, Struening EL, et al. Does outreach case management improve patients' quality of life?. Psychiatric services (Washington, D.C.). 1998:351-4. Exclusion Code: X2.
85 Cusack KJ, Morrissey JP, Cuddeback GS, et al. Criminal justice involvement, behavioral health service use, and costs of forensic assertive community treatment: a randomized trial. Community Ment Health J. Aug. 2010;46(4):356-63. Exclusion Code: X2. [pmid: 20217230].
86 Dahlan R, Midin M, Sidi H, et al. Hospital-based community psychiatric service for patients with schizophrenia in Kuala Lumpur: a 1-year follow-up study of re-hospitalization. Asia Pac Psychiatry. Apr. Suppl 1. 2013;5:127-33. Exclusion Code: X3. [pmid: 23857849].
87 Davidson L. Effectiveness and Cost Effectiveness of Peer Mentors in Reducing Hospital Use. 2012. Exclusion Code: X1.
88 Davidson L, Chinman M, Kloos B, et al. Peer support among individuals with severe mental illness: a review of the evidence. Clin Psychol (New York). 1999;6(2):165-87. Exclusion Code: X2.
89 Davidson L, Chinman M, Sells D, et al. Peer support among adults with serious mental illness: a report from the field. Schizophr Bull. Jul. 2006;32(3):443-50. Exclusion Code: X2. [pmid: 16461576].
90 Davidson L, Tebes JK, Rakfeldt J, et al. Differences in social environment between inpatient and day hospital-crisis respite settings. Psychiatr Serv. Jul. 1996;47(7):714-20. Exclusion Code: X2. [pmid: 8807684].
91 Davison S, Jamieson E, Taylor PJ. Route of discharge for special (high-security) hospital patients with personality disorder. Relationship with re-conviction. Br J Psychiatry. Sep. 1999;175:224-7. Exclusion Code: X2. [pmid: 10645322].
92 De Filippo E, Signorini A, Bracale R, et al. Hospital admission and mortality rates in anorexia nervosa: experience from an integrated medical-psychiatric outpatient treatment. Eat Weight Disord. Dec. 2000;5(4):211-6. Exclusion Code: X2. [pmid: 11216129].
93 Decker JB, Stubblebine JM. Crisis intervention and prevention of psychiatric disability: a follow-up study. Am J Psychiatry. Dec. 1972;129(6):725-9. Exclusion Code: X2. [pmid: 4638721].
94 Dellasega C, Dansky K, King L, et al. Use of home health services by elderly persons with cognitive impairment. J Nurs Adm. Jun. 1994;24(6):20-5. Exclusion Code: X2. [pmid: 8006698].
95 D'Ercole A, Struening E, Curtis JL, et al. Effects of diagnosis, demographic characteristics, and case management on rehospitalization. Psychiatr Serv. May. 1997;48(5):682-8. Exclusion Code: X2. [pmid: 9144824].
96 Ding R, McCarthy ML, Desmond JS, et al. Characterizing waiting room time, treatment time, and boarding time in the emergency department using quantile regression. Acad Emerg Med. Aug. 2010;17(8):813-23. Exclusion Code: X5. [pmid: 20670318].
97 Dixon L, Goldberg R, Iannone V, et al. Use of a critical time intervention to promote continuity of care after psychiatric inpatient hospitalization. Psychiatr Serv. Apr. 2009;60(4):451-8. Exclusion Code: X2. [pmid: 19339319].
98 Dott SG, Walling DP, Bishop SL, et al. The efficacy of short-term treatment for improving quality of life: a pilot study. J Nerv Ment Dis. Aug. 1996;184(8):507-9. Exclusion Code: X2. [pmid: 8752082].
99 Durst R, Teitelbaum A, Bar-El Y, et al. Evaluation of compulsory ambulatory treatment in Israel. Psychiatr Serv. May. 1999;50(5):698-700. Exclusion Code: X2. [pmid: 10332910].
100 Dyer C. Community treatment orders have not reduced admissions, study shows. BMJ. 2013;346:f1993. Exclusion Code: X1. [pmid: 23530016].
101 Edelsohn GA, Hiday VA. Civil commitment: a range of patient attitudes. Bull Am Acad Psychiatry Law. 1990;18(1):65-77. Exclusion Code: X2. [pmid: 2328335].
102 Edens JF, Peters RH, Hills HA. Treating prison inmates with co-occurring disorders: an integrative review of existing programs. Behav Sci Law. Autumn. 1997;15(4):439-57. Exclusion Code: X2. [pmid: 9433747].
103 Eisen SV, Wilcox M, Idiculla T, et al. Assessing consumer perceptions of inpatient psychiatric treatment: the perceptions of care survey. Jt Comm J Qual Improv. Sep. 2002;28(9):510-26. Exclusion Code: X2. [pmid: 12216348].
104 El YC, Durst R, Rabinowitz J, et al. Implementation of order of compulsory ambulatory treatment in Jerusalem. Int J Law Psychiatry. Winter. 1998;21(1):65-71. Exclusion Code: X2. [pmid: 9526716].
105 Fakhoury WK, White I, Priebe S. Be good to your patient: how the therapeutic relationship in the treatment of patients admitted to assertive outreach affects rehospitalization. J Nerv Ment Dis. Sep. 2007;195(9):789-91. Exclusion Code: X2. [pmid: 17984783].
106 Fee C, Burstin H, Maselli JH, et al. Association of emergency department length of stay with safety-net status. JAMA. Feb. 1. 2012;307(5):476-82. Exclusion Code: X5. [pmid: 22298679].
107 Felton CJ, Stastny P, Shern DL, et al. Consumers as peer specialists on intensive case management teams: impact on client outcomes. Psychiatr Serv. Oct. 1995;46(10):1037-44. Exclusion Code: X2. [pmid: 8829785].
108 Fenton WS, Mosher L. Crisis residential care for patients with serious mental illness. Martindale B, Bateman A, Margison F, editors. Psychosis: Psychological Approaches and Their Effectiveness. London, UK. Gaskell–Royal College of Psychiatrists. 2000. Exclusion Code: X1.
109 Fernandez GA. Evaluation of involuntary outpatient commitment in North Carolina. Raleigh, NC. North Carolina Division of Mental Health, Developmental Disabilities, and Substance Abuse Services. 1992. Exclusion Code: X8-Irretrievable.
110 Fetter MS, Lowery BJ, Fetter MS, et al. Attributions for readmission schizophrenic patients. Psychiatric rehospitalization of the severely mentally ill: Patient and staff perspectives. 1992;41:301-5. Exclusion Code: X3.
111 Fiander M, Burns T, McHugo GJ, et al. Assertive community treatment across the Atlantic: comparison of model fidelity in the UK and USA. Br J Psychiatry. Mar. 2003;182:248-54. Exclusion Code: X5. [pmid: 12611789].
112 Fiorillo A, De Rosa C, Del Vecchio V, et al. How to improve clinical practice on involuntary hospital admissions of psychiatric patients: suggestions from the EUNOMIA study. Eur Psychiatry. May. 2011;26(4):201-7. Exclusion Code: X3. [pmid: 20965119].
113 Fontanella CA, Zuravin SJ, Burry CL. The effect of a medicaid managed care program on patterns of psychiatric readmission among adolescents: evidence from Maryland. J Behav Health Serv Res. Jan. 2006;33(1):39-52. Exclusion Code: X2. [pmid: 16636907].
114 Forchuk C, MacClure SK, Van Beers M, et al. Developing and testing an intervention to prevent homelessness among individuals discharged from psychiatric wards to shelters and 'No Fixed Address'. J Psychiatr Ment Health Nurs. Sep. 2008;15(7):569-75. Exclusion Code: X5. [pmid: 18768009].
115 Frederick S, Caldwell K, Rubio DM. Home-based treatment, rates of ambulatory follow-up, and psychiatric rehospitalization in a Medicaid managed care population. J Behav Health Serv Res. Nov. 2002;29(4):466-75. Exclusion Code: X2. [pmid: 12404940].
116 Freeland A, O'Brien A, Farrell SJ. The impact of community treatment orders on patients with assertive community treatment and without. 29th International Congress on Law and Mental Health. 2005. Paris, France. International Academy of Law and Mental Health. Exclusion Code: X8.
117 Froland C, Brodsky G, Olson M, et al. Social support and social adjustment: implications for mental health professionals. Community Ment Health J. Feb 2000. 2000;36(1):61-75. Exclusion Code: X5.
118 Fukui S, Starnino VR, Susana M, et al. Effect of Wellness Recovery Action Plan (WRAP) participation on psychiatric symptoms, sense of hope, and recovery. Psychiatr Rehabil J. Winter. 2011;34(3):214-22. Exclusion Code: X2. [pmid: 21208860].
119 Gallas C, Dressing H, Hess N, et al. S22-01 - Preventive monitoring of psychiatric patients at risk for compulsory readmission: preliminary results of a multi-center RCT. Eur Psychiatry. Supplement 1. 2010;25(0):86. Exclusion Code: X1.
120 Gandhi N, Tyrer P, Evans K, et al. A randomized controlled trial of community-oriented and hospital-oriented care for discharged psychiatric patients: influence of personality disorder on police contacts. J Pers Disord. Feb. 2001;15(1):94-102. Exclusion Code: X2. [pmid: 11236818].
121 Garrido P, Saraiva CB. P-601 - Understanding the revolving door syndrome. Eur Psychiatry. 2012;27:1. Exclusion Code: X1. [pmid: 22153731].
122 Geller JL, McDermeit M, Grudzinskas AJ Jr, et al. A competency-based approach to court-ordered outpatient treatment. New Dir Ment Health Serv. 1997;Fall(75):81-95. Exclusion Code: X2. [pmid: 9283196].
123 Gervey R, Bedell JR. Supported employment in vocational rehabilitation. Bedell JR, editor. Psychological assessment and treatment of persons with severe mental disorders. Washington, D.C. Taylor and Francis. 1994:170-5. Exclusion Code: X2.
124 Gibbs A, Dawson J, Forsyth H, et al. Maori experience of community treatment orders in Otago, New Zealand. Aust N Z J Psychiatry. Oct. 2004;38(10):830-5. Exclusion Code: X5. [pmid: 15369542].
125 Gibbs A, Dawson J, Mullen R. Community Treatment Orders for People with Serious Mental Illness: A New Zealand Study. Br J Social Work. Oct 2006. 2006;36(7):1085-100. Exclusion Code: X5.
126 Gilbert AR, Moser LL, Van Dorn RA, et al. Reductions in arrest under assisted outpatient treatment in New York. Psychiatr Serv. Oct. 2010;61(10):996-9. Exclusion Code: X5. [pmid: 20889637].
127 Gilburt H, Slade M, Rose D, et al. Service users' experiences of residential alternatives to standard acute wards: qualitative study of similarities and differences. Br J Psychiatry Suppl. Aug. 2010;53:s26-31. Exclusion Code: X5. [pmid: 20679276].
128 Glover G, Arts G, Babu KS. Crisis resolution/home treatment teams and psychiatric admission rates in England. Br J Psychiatry. Nov. 2006;189:441-5. Exclusion Code: X2. [pmid: 17077435].
129 Goethe JW, Dornelas EA, Gruman C. Predicting service utilization after psychiatric hospitalization. Compr Psychiatry. May-Jun. 1999;40(3):192-7. Exclusion Code: X2. [pmid: 10360613].
130 Gold PB, Meisler N, Santos AB, et al. The Program of Assertive Community Treatment: Implementation and dissemination of an evidence-based model of community-based care for persons with severe and persistent mental illness. Cog Behav Pract. 2003;10:290-303. Exclusion Code: X2.
131 Golkaramnay V, Bauer S, Haug S, et al. The exploration of the effectiveness of group therapy through an Internet chat as aftercare: a controlled naturalistic study. Psychother Psychosom. 2007;76(4):219-25. Exclusion Code: X2. [pmid: 17570960].
132 Granholm E, Anthenelli R, Monteiro R, et al. Brief integrated outpatient dual-diagnosis treatment reduces psychiatric hospitalizations. Am J Addict. Jul-Sep. 2003;12(4):306-13. Exclusion Code: X2. [pmid: 14504023].
133 Green BH, Griffiths EC. Hospital admission and community treatment of mental disorders in England from 1998 to 2012. Gen Hosp Psychiatry. 2014;36(4):442-8. Exclusion Code: X2. [pmid: 24726764].
134 Greenfield TK, Stoneking BC, Humphreys K, et al. A randomized trial of a mental health consumer-managed alternative to civil commitment for acute psychiatric crisis. Am J Community Psychol. Sep. 2008;42(1-2):135-44. Exclusion Code: X2. [pmid: 18626766].
135 Guo S, Biegel DE, Johnsen JA, et al. Assessing the impact of community-based mobile crisis services on preventing hospitalization. Psychiatr Serv. Feb. 2001;52(2):223-8. Exclusion Code: X2. [pmid: 11157123].
136 Hansen LO, Young RS, Hinami K, et al. Interventions to reduce 30-day rehospitalization: a systematic review (Structured abstract). Ann Intern Med. 2011:520-8. Exclusion Code: X2. [pmid: 22007045].
137 Hawthorne W, Mosher L, Lohr J, et al. San Diego County Inpatient Client Satisfaction Survey (CSS). San Diego, CA. Community Research Foundation. 1998. Exclusion Code: X1.
138 Hawthorne WB, Green EE, Folsom D, et al. A randomized study comparing the treatment environment in alternative and hospital-based acute psychiatric care. Psychiatr Serv. Sep. 2009;60(9):1239-44. Exclusion Code: X2. [pmid: 19723739].
139 Hawthorne WB, Green EE, Gilmer T, et al. A randomized trial of short-term acute residential treatment for veterans (Structured abstract). Psychiatr Serv. 2005:1379-86. Exclusion Code: X2. [pmid: 16282256].
140 Hawthorne WB, Green EE, Lohr JB, et al. Comparison of outcomes of acute care in short-term residential treatment and psychiatric hospital settings (Structured abstract). Psychiatr Serv. 1999:401-6. Exclusion Code: X2. [pmid: 10096647].
141 Haycox A, Unsworth L, Allen K, et al. North Staffordshire Community Beds Study: longitudinal evaluation of psychiatric in-patient units attached to community mental health centres. 2: Impact upon costs and resource use. Br J Psychiatry. Jul. 1999;175:79-86. Exclusion Code: X5. [pmid: 10621772].
142 Heeren O, Dixon L, Gavirneni S, et al. The association between decreasing length of stay and readmission rate on a psychogeriatric unit. Psychiatr Serv. Jan. 2002;53(1):76-9. Exclusion Code: X2. [pmid: 11773653].
143 Henderson C, Flood C, Leese M, et al. Effect of joint crisis plans on use of compulsory treatment in psychiatry: single blind randomised controlled trial. BMJ. Jul. 17. 2004;329(7458):136. Exclusion Code: X3. [pmid: 15240438].
144 Henry J, McGORRY P, Jane E, et al. A controlled trial of cognitively oriented psychotherapy for early psychosis (COPE) with four-year follow-up readmission data. Psychol Med. 2005;35(9):1295-306. Exclusion Code: X2. [pmid: 16168152].
145 Herman DB, Conover S, Gorroochurn P, et al. Randomized trial of critical time intervention to prevent homelessness after hospital discharge. Psychiatr Serv. Jul. 2011;62(7):713-9. Exclusion Code: X2. [pmid: 21724782].
146 Hickey T, Moran R, Walsh D. Psychiatric Day Care - An Underused Option?. The Purposes and Functions of Psychiatric Day Hospitals and Day Centres: A Study In Two Health Boards. Health Research Board. Dublin, Ireland. 2003. Exclusion Code: X2.
147 Hirsch C. ACP Journal Club. Review: case management does not reduce unplanned hospital admissions compared with usual care in older persons. Ann Intern Med. Jun. 18. 2013;158(12):JC13. Exclusion Code: X2. [pmid: 23778925].
148 Ho TP. Duration of hospitalization and post discharge suicide. Suicide Life Threat Behav. Dec. 2006;36(6):682-6. Exclusion Code: X5. [pmid: 17250472].
149 Hobbs H, Wilson JH, Archie S. Evaluation of the Alumni Program. A shared-care model for psychosis. J Psychosoc Nurs Ment Health Serv. Jan. 2004;42(1):28-36. Exclusion Code: X2. [pmid: 14768277].
150 Horvitz-Lennon M, Normand SL, Gaccione P, et al. Partial versus full hospitalization for adults in psychiatric distress: a systematic review of the published literature (1957-1997). Am J Psychiatry. May. 2001;158(5):676-85. Exclusion Code: X2. [pmid: 11329384].
151 Howard L, Flach C, Leese M, et al. Effectiveness and cost-effectiveness of admissions to women's crisis houses compared with traditional psychiatric wards: pilot patient-preference randomised controlled trial. Br J Psychiatry Suppl. Aug. 2010;53:s32-40. Exclusion Code: X2. [pmid: 20679277].
152 Hughes SL, Ulasevich A, Weaver FM, et al. Impact of home care on hospital days: a meta analysis (Structured abstract). Health Serv Res. 1997:415-32. Exclusion Code: X1. [pmid: 9327811].
153 Hugo M, Smout M, Bannister J. A comparison in hospitalization rates between a community-based mobile emergency service and a hospital-based emergency service. Aust N Z J Psychiatry. Aug. 2002;36(4):504-8. Exclusion Code: X2. [pmid: 12169150].
154 Humphreys K, Rappaport J. Researching self-help/mutual aid groups and organizations: Many roads, one journey. Appl Prev Psychol. 1994;3(4):217-31. Exclusion Code: X5.
155 Hunt AM, da Silva A, Lurie S, et al. Community treatment orders in Toronto: the emerging data. Can J Psychiatry. Oct. 2007;52(10):647-56. Exclusion Code: X2. [pmid: 18020112].
156 Ingram G, Muirhead D, Harvey C. Effectiveness of community treatment orders for treatment of schizophrenia with oral or depot antipsychotic medication: changes in problem behaviours and social functioning. Aust N Z J Psychiatry. Nov. 2009;43(11):1077-83. Exclusion Code: X2. [pmid: 20001403].
157 Janzen R, Nelson G, Trainor J, et al. A Longitudinal study of mental health consumer/survivor initiatives: Part 4—Benefits beyond the self? A quantitative and qualitative study of system-level activities and impacts. J Community Psychol. 2006;34(3):285-303. Exclusion Code: X2. [pmid: 20391788].
158 Jerrell JM. Toward managed care for persons with severe mental illness: implications from a cost-effectiveness study. Health Aff (Millwood). Fall. 1995;14(3):197-207. Exclusion Code: X5. [pmid: 7498892].
159 Johannessen HA, Dieserud G, Jakhelln F, et al. Changes in institutional psychiatric care and suicidal behaviour: a follow-up study of inpatient suicide attempters in Baerum, Norway. Soc Psychiatry Psychiatr Epidemiol. Oct. 2009;44(10):845-51. Exclusion Code: X2. [pmid: 19247559].
160 Johnson DK, Niedens M, Wilson JR, et al. Treatment outcomes of a crisis intervention program for dementia with severe psychiatric complications: the Kansas bridge project. Gerontologist. Feb. 2013;53(1):102-12. Exclusion Code: X2. [pmid: 22936530].
161 Johnson S, Bingham C, Billings J, et al. Women's experiences of admission to a crisis house and to acute hospital wards: a qualitative study. Journal of Mental Health. Jun 2004. 2004;13(3):247-62. Exclusion Code: X2.
162 Johnson S, Nolan F, Pilling S, et al. Randomised controlled trial of acute mental health care by a crisis resolution team: The north Islington crisis study. BMJ: British Medical Journal. 2005;331(7517):599. Exclusion Code: X2.
163 Johnstone P, Zolese G. Systematic review of the effectiveness of planned short hospital stays for mental health care. BMJ. May. 22. 1999;318(7195):1387-90. Exclusion Code: X2. [pmid: 10334748].
164 Jonikas JA, Grey DD, Copeland ME, et al. Improving propensity for patient self-advocacy through wellness recovery action planning: results of a randomized controlled trial. Community Ment Health J. Jun. 2013;49(3):260-9. Exclusion Code: X2. [pmid: 22167660].
165 Joo JY, Huber DL. An integrative review of nurse-led community-based case management effectiveness. Int Nurs Rev. 2014;61(1):14-24. Exclusion Code: X2. [pmid: 24218992].
166 Kallert T, Priebe S, Schützwohl M, et al. The role of acute day hospital treatment for mental health care: Research context and practical problems of carrying out the international multi-centre EDEN-study. Kirch W, editor. Public Health in Europe. Springer. Berlin Heidelberg. 2004:153-71. Exclusion Code: X2.
167 Kallert TW, Matthes C, Glöckner M, et al. Acute psychiatric day hospital treatment: is the effectiveness of this treatment approach still questionable?. Psychiatr Prax. 2004:409-19. Exclusion Code: X1. [pmid: 15546056].
168 Kallert TW, Priebe S, McCabe R, et al. Are day hospitals effective for acutely ill psychiatric patients? A European multicenter randomized controlled trial. J Clin Psychiatry. Feb. 2007;68(2):278-87. Exclusion Code: X2. [pmid: 17335327].
169 Kallert TW, Schützwohl M, Kiejna A, et al. Efficacy of psychiatric day hospital treatment: Review of research findings and design of a European multi-center study. Archives of psychiatry and psychotherapy. 2002;4(2):55-71. Exclusion Code: X2.
170 Karniel-Lauer E, Szor H, Livne S, et al. The "re-entry group"--a transitional therapeutic framework for mentally ill patients discharged from the hospital to community clinics. Can J Psychiatry. Nov. 2000;45(9):837-9. Exclusion Code: X2. [pmid: 11143835].
171 Kates N, Craven M. Shared mental health care. Update from the Collaborative Working Group of the College of Family Physicians of Canada and the Canadian Psychiatric Association. Can Fam Physician. May. 2002;48:936. Exclusion Code: X5. [pmid: 12053639].
172 Kaufmann CL. The Self Help Employment Center: Some outcomes from the first year. Psychosoc Rehab J. Spr. 1995;18(4):145-62. Exclusion Code: X2.
173 Kaufmann CL, Ward-Colasante C, Farmer J. Development and evaluation of drop-in centers operated by mental health consumers. Hosp Community Psychiatry. Jul. 1993;44(7):675-8. Exclusion Code: X2. [pmid: 8354507].
174 Khaleghparast S, Ghanbari B, Kahani S, et al. The effectiveness of discharge planning on the knowledge, clinical symptoms and hospitalisation frequency of persons with schizophrenia: a longitudinal study in two hospitals in Tehran, Iran. J Clin Nurs. 2014;23(15/16):2215-22. Exclusion Code: X2. [pmid: 24329909].
175 Khazaal Y, Chatton A, Pasandin N, et al. Advance directives based on cognitive therapy: a way to overcome coercion related problems. Patient Educ Couns. Jan. 2009;74(1):35-8. Exclusion Code: X3. [pmid: 18829211].
176 Kikuchi H, Abo M, Kumakura E, et al. Efficacy of continuous follow-up for preventing the involuntary readmission of psychiatric patients in Japan: a retrospective cohort study. Int J Soc Psychiatry. May. 2013;59(3):288-95. Exclusion Code: X2. [pmid: 22249464].
177 Kim HM, Pfeiffer P, Ganoczy D, et al. Intensity of outpatient monitoring after discharge and psychiatric rehospitalization of veterans with depression. Psychiatr Serv. Nov. 2011;62(11):1346-52. Exclusion Code: X3. [pmid: 22211215].
178 Kim YJ, Soeken KL. A meta-analysis of the effect of hospital-based case management on hospital length-of-stay and readmission (Structured abstract). Nurs Res. 2005:255-64. Exclusion Code: X2. [pmid: 16027568].
179 Kisely S, Campbell LA, Preston NJ, et al. Can epidemiological studies assist in the evaluation of community treatment orders? - The experience of Western Australia and Nova Scotia. Int J Law Psychiatry. Nov-Dec. 2006;29(6):507-15. Exclusion Code: X2. [pmid: 17067675].
180 Kisely S, Campbell LA, Scott A, et al. Randomized and non-randomized evidence for the effect of compulsory community and involuntary out-patient treatment on health service use: systematic review and meta-analysis (Structured abstract). Psychol Med. 2007:3-14. Exclusion Code: X1. [pmid: 16923325].
181 Kisely S, Preston N, Xiao J, et al. Reducing all-cause mortality among patients with psychiatric disorders: a population-based study. CMAJ. Jan. 8. 2013;185(1):E50-6. Exclusion Code: X5. [pmid: 23148054].
182 Kisely S, Xiao J, Lawrence D, et al. Is the effect of compulsory community treatment on preventable deaths from physical disorders mediated by better access to specialized medical procedures?. Can J Psychiatry. Jan. 2014;59(1):54-8. Exclusion Code: X2. [pmid: 24444325].
183 Kisely SR, Xiao J, Preston NJ. Impact of compulsory community treatment on admission rates: survival analysis using linked mental health and offender databases. Br J Psychiatry. May. 2004;184:432-8. Exclusion Code: X2. [pmid: 15123508].
184 Kisely Steve R, Campbell Leslie A, Preston Neil J. Compulsory community and involuntary outpatient treatment for people with severe mental disorders. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011. Exclusion Code: X1.
185 Klug G, Hermann G, Fuchs-Nieder B, et al. Geriatric psychiatry home treatment (GHT): a pilot study on outcomes following hospital discharge for depressive and delusional patients. Arch Gerontol Geriatr. Jul-Aug. 2008;47(1):109-20. Exclusion Code: X2. [pmid: 17945364].
186 Kluiter H, Giel R, Nienhuis FJ, et al. Predicting feasibility of day treatment for unselected patients referred for inpatient psychiatric treatment: results of a randomized trial. Am J Psychiatry. Sep. 1992;149(9):1199-205. Exclusion Code: X2. [pmid: 1503133].
187 Knapp M, Beecham J, Koutsogeorgopoulou V, et al. Service use and costs of home-based versus hospital-based care for people with serious mental illness. Br J Psychiatry. Aug. 1994;165(2):195-203. Exclusion Code: X2. [pmid: 7953032].
188 Kopelowicz A, Wallace CJ, Zarate R. Teaching psychiatric inpatients to re-enter the community: a brief method of improving the continuity of care. Psychiatr Serv. Oct. 1998;49(10):1313-6. Exclusion Code: X2. [pmid: 9779901].
189 Korkeila JA, Karlsson H, Kujari H. Factors predicting readmissions in personality disorders and other nonpsychotic illnesses. A retrospective study on 64 first-ever admissions to the Psychiatric Clinic of Turku, Finland. Acta Psychiatr Scand. Aug. 1995;92(2):138-44. Exclusion Code: X2. [pmid: 7572260].
190 Kortrijk HE, Staring AB, van Baars AW, et al. Involuntary admission may support treatment outcome and motivation in patients receiving assertive community treatment. Soc Psychiatry Psychiatr Epidemiol. Feb. 2010;45(2):245-52. Exclusion Code: X5. [pmid: 19412561].
191 Krebaum SR. Mental health consumers as case management aides in the transition from hospital to community: Outcome of consumers served (consumer-provided. US. ProQuest Information & Learning. 1999. Exclusion Code: X2.
192 Krivoy A, Fischel T, Zahalka H, et al. Outcomes of compulsorily admitted schizophrenia patients who agreed or disagreed to prolong their hospitalization. Compr Psychiatry. Oct. 2012;53(7):995-9. Exclusion Code: X3. [pmid: 22520086].
193 Kuhlman TL. Unavoidable tragedies in Madison, Wisconsin: a third view. Hosp Community Psychiatry. Jan. 1992;43(1):72-3. Exclusion Code: X2. [pmid: 1520351].
194 Kyle T, Dunn JR. Effects of housing circumstances on health, quality of life and healthcare use for people with severe mental illness: a review. Health Soc Care Community. Jan. 2008;16(1):1-15. Exclusion Code: X1. [pmid: 18181811].
195 Lambert M, Bock T, Schottle D, et al. Assertive community treatment as part of integrated care versus standard care: a 12-month trial in patients with first- and multiple-episode schizophrenia spectrum disorders treated with quetiapine immediate release (ACCESS trial). J Clin Psychiatry. Oct. 2010;71(10):1313-23. Exclusion Code: X5. [pmid: 20361911].
196 Landers GM, Zhou M. An analysis of relationships among peer support, psychiatric hospitalization, and crisis stabilization. Community Ment Health J. Feb. 2011;47(1):106-12. Exclusion Code: X2. [pmid: 19551502].
197 Längle G, Bayer W, Köster M, et al. Do the effects of inpatient vocational therapy and ergotherapy approaches differ in schizophrenic patients? Results of a controlled multicenter study of the german research network on schizophrenia. Psychiatr Prax. 2006:34-41. Exclusion Code: X1. [pmid: 16389581].
198 Lawn S, Smith A, Hunter K. Mental health peer support for hospital avoidance and early discharge: An Australian example of consumer driven and operated service. Journal of Mental Health. Oct 2008. 2008;17(5):498-508. Exclusion Code: X2.
199 Lee S, Rothbard AB, Noll EL. Length of inpatient stay of persons with serious mental illness: effects of hospital and regional characteristics. Psychiatr Serv. Sep. 1. 2012;63(9):889-95. Exclusion Code: X5. [pmid: 22751995].
200 Lehman AF, Herron JD, Schwartz RP, et al. Rehabilitation for adults with severe mental illness and substance use disorders. A clinical trial. J Nerv Ment Dis. Feb. 1993;181(2):86-90. Exclusion Code: X2. [pmid: 8426176].
201 Lesage A. Regional tertiary psychiatric care and rehabilitation authorities for people with severe mental illness in Canada. Canadian Journal of Psychiatry. Revue Canadienne de Psychiatrie. Apr. 2014;59(4):175-7. Exclusion Code: X5. [pmid: 25007109].
202 Leung D, De Sousa L. A Vision and Mission for Peer Support - Stakeholder Perspectives. International Journal of Psychosocial Rehabilitation. 2002;7:5-14. Exclusion Code: X2.
203 Lien L. Are readmission rates influenced by how psychiatric services are organized?. Nord J Psychiatr. 2002;56(1):23-8. Exclusion Code: X2. [pmid: 6263252].
204 Lin HC, Tian WH, Chen CS, et al. The association between readmission rates and length of stay for schizophrenia: a 3-year population-based study. Schizophr Res. Apr. 2006;83(2-3):211-4. Exclusion Code: X2. [pmid: 16504482].
205 Link BG, Epperson MW, Perron BE, et al. Arrest outcomes associated with outpatient commitment in New York State. Psychiatr Serv. May. 2011;62(5):504-8. Exclusion Code: X5. [pmid: 21532076].
206 Linszen D, Dingemans P, Van der Does JW, et al. Treatment, expressed emotion and relapse in recent onset schizophrenic disorders. Psychol Med. Mar. 1996;26(2):333-42. Exclusion Code: X2. [pmid: 8685289].
207 Lloyd-Evans B, Johnson S, Morant N, et al. Alternatives to standard acute in-patient care in England: differences in content of care and staff-patient contact. Br J Psychiatry Suppl. Aug. 2010;53:s46-51. Exclusion Code: X5. [pmid: 20679280].
208 Lloyd-Evans B, Slade M, Jagielska D, et al. Residential alternatives to acute psychiatric hospital admission: systematic review. Br J Psychiatry. Aug. 2009;195(2):109-17. Exclusion Code: X2. [pmid: 19648539].
209 Luchins DJ, Hanrahan P, Conrad KJ, et al. An agency-based representative payee program and improved community tenure of persons with mental illness. Psychiatr Serv. Sep. 1998;49(9):1218-22. Exclusion Code: X2. [pmid: 9735966].
210 Luettgen J, Chrapko WE, Reddon JR. Preventing violent re-offending in not criminally responsible patients. An evaluation of a continuity of treatment program. Int J Law Psychiatry. Winter. 1998;21(1):89-98. Exclusion Code: X2. [pmid: 9526718].
211 Lyons JS, Cook JA, Ruth AR, et al. Service delivery using consumer staff in a mobile crisis assessment program. Community Ment Health J. Feb. 1996;32(1):33-40. Exclusion Code: X2. [pmid: 8635315].
212 Lyons JS, O'Mahoney MT, Miller SI, et al. Predicting readmission to the psychiatric hospital in a managed care environment: implications for quality indicators. Am J Psychiatry. Mar. 1997;154(3):337-40. Exclusion Code: X2. [pmid: 9054780].
213 Macias C, Kinney R, Farley OW, et al. The role of case management within a community support system: partnership with psychosocial rehabilitation. Community Ment Health J. Aug. 1994;30(4):323-39. Exclusion Code: X2. [pmid: 7956109].
214 Malone D, Marriott S, Newton-Howes G, et al. Community mental health teams (CMHTs) for people with severe mental illnesses and disordered personality. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2007. Exclusion Code: X1.
215 Mancini AD, Moser LL, Whitley R, et al. Assertive community treatment: facilitators and barriers to implementation in routine mental health settings. Psychiatr Serv. Feb. 2009;60(2):189-95. Exclusion Code: X2. [pmid: 19176412].
216 Mares A, McGuire J. Reducing psychiatric hospitalization among mentally ill veterans living in board-and-care homes. Psychiatr Serv. Jul. 2000;51(7):914-21. Exclusion Code: X2. [pmid: 10875958].
217 Mark T, Tomic KS, Kowlessar N, et al. Hospital readmission among medicaid patients with an index hospitalization for mental and/or substance use disorder. J Behav Health Serv Res. Apr. 2013;40(2):207-21. Exclusion Code: X2. [pmid: 23430287].
218 Marks IM, Connolly J, Muijen M, et al. Home-based versus hospital-based care for people with serious mental illness. Br J Psychiatry. Aug. 1994;165(2):179-94. Exclusion Code: X2. [pmid: 7953031].
219 Marshall M, Crowther R, Almaraz-Serrano A, et al. Systematic reviews of the effectiveness of day care for people with severe mental disorders: (1) acute day hospital versus admission; (2) vocational rehabilitation; (3) day hospital versus outpatient care. Health Technol Assess. 2001;5(21):1-75. Exclusion Code: X2. [pmid: 11532238].
220 Marshall M, Crowther R, Almaraz-Serrano AM, et al. Day hospital versus out-patient care for psychiatric disorders. Cochrane Database Syst Rev. 2001;(3):CD003240. Exclusion Code: X2. [pmid: 11687059].
221 Marshall M, Gray A, Lockwood A, et al. Case management for people with severe mental disorders. Cochrane Database Syst Rev. 2000;(2):CD000050. Exclusion Code: X2. [pmid: 10796288].
222 Masso JD, Avi-Itzhak T, Obler DR. The clubhouse model: An outcome study on attendance, work attainment and status, and hospitalization recidivism. Work. 2001;17(1):23-30. Exclusion Code: X3. [pmid: 12441619].
223 Masters GA, Baldessarini RJ, Ongur D, et al. Factors associated with length of psychiatric hospitalization. Compr Psychiatry. Apr. 2014;55(3):681-7. Exclusion Code: X3. [pmid: 24387922].
224 Mayahara K, Ito H. Readmission of discharged schizophrenic patients with and without day care in Japan. International Medical Journal. 2002;9(2):121-3. Exclusion Code: X2.
225 Mbaya P, Creed F, Tomenson B. The different uses of day hospitals. Acta Psychiatr Scand. 1998;98(4):283-7. Exclusion Code: X2. [pmid: 9821449].
226 McCrone P, Beecham J, Knapp M. Community psychiatric nurse teams: cost-effectiveness of intensive support versus generic care. Br J Psychiatry. Aug. 1994;165(2):218-21. Exclusion Code: X2. [pmid: 7953035].
227 McDonnell E, Bartholomew T. Community treatment orders in Victoria: Emergent issues and anomalies. Psychiatry Psychol. & L. 1997;4(1):25-36. Exclusion Code: X2.
228 McFarlane WR, Dushay RA, Deakins SM, et al. Employment outcomes in family-aided assertive community treatment. Am J Orthopsychiatry. Apr. 2000;70(2):203-14. Exclusion Code: X2. [pmid: 10826032].
229 McFarlane WR, Lukens E, Link B, et al. Multiple-family groups and psychoeducation in the treatment of schizophrenia. Arch Gen Psychiatry. Aug. 1995;52(8):679-87. Exclusion Code: X2. [pmid: 7632121].
230 McIntosh J, Worley N. Beyond discharge: telephone follow-up and aftercare. J Psychosoc Nurs Ment Health Serv. Oct. 1994;32(10):21-7. Exclusion Code: X2. [pmid: 7844766].
231 Meiser-Stedman C, Howard L, Cutting P. Evaluating the Effectiveness of a Women's Crisis House: A Prospective Observational Study. Psychiatric Bulletin. Sep 2006. 2006;30(9):324-6. Exclusion Code: X2.
232 Merson S, Tyrer P, Carlen D, et al. The cost of treatment of psychiatric emergencies: a comparison of hospital and community services. Psychol Med. Jul. 1996;26(4):727-34. Exclusion Code: X2. [pmid: 8817707].
233 Merson S, Tyrer P, Onyett S, et al. Early intervention in psychiatric emergencies: a controlled clinical trial. Lancet. May. 30. 1992;339(8805):1311-4. Exclusion Code: X2. [pmid: 1349990].
234 Miller P, Gladman JR, Cunliffe AL, et al. Economic analysis of an early discharge rehabilitation service for older people (Structured abstract). Age Ageing. 2005:274-80. Exclusion Code: X2. [pmid: 15764621].
235 Milne D, O'Brien A, McKenna B. Community treatment orders and competence to consent. Australas Psychiatry. Aug. 2009;17(4):273-8. Exclusion Code: X5. [pmid: 19585289].
236 Milne R, Clarke A. Can readmission rates be used as an outcome indicator?. BMJ. Nov. 17. 1990;301(6761):1139-40. Exclusion Code: X3. [pmid: 2252926].
237 Min SY, Whitecraft J, Rothbard AB, et al. Peer support for persons with co-occurring disorders and community tenure: a survival analysis. Psychiatr Rehabil J. Winter. 2007;30(3):207-13. Exclusion Code: X2. [pmid: 17269271].
238 Mistiaen P, Poot E. Telephone follow-up, initiated by a hospital-based health professional, for postdischarge problems in patients discharged from hospital to home. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2006. Exclusion Code: X2.
239 Mojtabai R, Nicholson RA, Neesmith DH. Factors affecting relapse in patients discharged from a public hospital: results from survival analysis. Psychiatr Q. Summer. 1997;68(2):117-29. Exclusion Code: X2. [pmid: 9114469].
240 Morriss R, Vinjamuri I, Faizal Mohammad A, et al. Training to recognise the early signs of recurrence in schizophrenia. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2013. Exclusion Code: X1.
241 Morse GA, Calsyn RJ, Allen G, et al. Experimental comparison of the effects of three treatment programs for homeless mentally ill people. Hosp Community Psychiatry. Oct. 1992;43(10):1005-10. Exclusion Code: X2. [pmid: 1398563].
242 Mowbray CT, Moxley DP, Collins ME. Consumers as mental health providers: first-person accounts of benefits and limitations. J Behav Health Serv Res. Nov. 1998;25(4):397-411. Exclusion Code: X2. [pmid: 9796162].
243 Mueser KT, Bond GR, Drake RE, et al. Models of community care for severe mental illness: a review of research on case management. Schizophr Bull. 1998;24(1):37-74. Exclusion Code: X5. [pmid: 9502546].
244 Muirhead D, Harvey C, Ingram G. Effectiveness of community treatment orders for treatment of schizophrenia with oral or depot antipsychotic medication: clinical outcomes. Aust N Z J Psychiatry. Jun-Jul. 2006;40(6-7):596-605. Exclusion Code: X7. [pmid: 16756586].
245 Muirhead D, Ingram G, Harvey C. Involuntary treatment of schizophrenia in the community: Clinical effectiveness of community treatment orders with oral or depot medication in Victoria. Aust N Z J Psychiatry. 2001;35(4):A20-A. Exclusion Code: X5.
246 Munetz MR, Ritter C, Teller JL, et al. Mental health court and assisted outpatient treatment: perceived coercion, procedural justice, and program impact. Psychiatr Serv. Mar. 1. 2014;65(3):352-8. Exclusion Code: X5. [pmid: 24036617].
247 Murphy S, Irving Claire B, Adams Clive E, et al. Crisis intervention for people with severe mental illnesses. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012. Exclusion Code: X2.
248 Myklebust LH, Sorgaard K, Wynn R. Local psychiatric beds appear to decrease the use of involuntary admission: a case-registry study. BMC Health Serv Res. 2014;14:64. Exclusion Code: X2. [pmid: 24506810].
249 Nelson EA, Maruish ME, Axler JL. Effects of discharge planning and compliance with outpatient appointments on readmission rates. Psychiatr Serv. Jul. 2000;51(7):885-9. Exclusion Code: X2. [pmid: 10875952].
250 Nelson G, Ochocka J, Janzen R, et al. A longitudinal study of mental health consumer/survivor initiatives: Part 1—Literature review and overview of the study. J Community Psychol. 2006;34(3):247-60. Exclusion Code: X2. [pmid: 20391791].
251 Nelson G, Ochocka J, Janzen R, et al. A longitudinal study of mental health consumer/survivor initiatives: Part V–Outcomes at 3-year follow-up. J Community Psychol. 2007;35(5):655-65. Exclusion Code: X2. [pmid: 25353926].
252 Niehaus DJ, Koen L, Galal U, et al. Crisis discharges and readmission risk in acute psychiatric male inpatients. BMC Psychiatry. 2008;8:44. Exclusion Code: X2. [pmid: 18559078].
253 Nienhuis FJ, Giel R, Kluiter H, et al. Efficacy of psychiatric day treatment. Course and outcome of psychiatric disorders in a randomised trial. Eur Arch Psychiatry Clin Neurosci. 1994;244(2):73-80. Exclusion Code: X2. [pmid: 7948057].
254 Nurjannah I, Mills J, Usher K, et al. Discharge planning in mental health care: an integrative review of the literature. J Clin Nurs. 2014;23(9/10):1175-85. Exclusion Code: X2. [pmid: 23844598].
255 O'Brien AM, Farrell SJ, Faulkner S. Community treatment orders: beyond hospital utilization rates examining the association of community treatment orders with community engagement and supportive housing. Community Ment Health J. Dec. 2009;45(6):415-9. Exclusion Code: X5. [pmid: 19728089].
256 O'Donoghue B, Roche E, Shannon S, et al. Perceived coercion in voluntary hospital admission. Psychiatry Res. Jan. 30. 2014;215(1):120-6. Exclusion Code: X3. [pmid: 24210740].
257 Olfson M, Mechanic D, Boyer CA, et al. Linking inpatients with schizophrenia to outpatient care. Psychiatr Serv. Jul. 1998;49(7):911-7. Exclusion Code: X2. [pmid: 9661225].
258 Osborn DP, Lloyd-Evans B, Johnson S, et al. Residential alternatives to acute in-patient care in England: satisfaction, ward atmosphere and service user experiences. Br J Psychiatry Suppl. Aug. 2010;53:s41-5. Exclusion Code: X2. [pmid: 20679279].
259 Owen C, Rutherford V, Jones M, et al. Psychiatric rehospitalization following hospital discharge. Community Ment Health J. Feb. 1997;33(1):13-24. Exclusion Code: X2. [pmid: 9061259].
260 Owens N, Brophy L. Revocation of Community Treatment Orders in a mental health service network. Australas Psychiatry. Feb. 2013;21(1):46-50. Exclusion Code: X5. [pmid: 23236095].
261 Paulson R, Herinckx H, Demmler J, et al. Comparing practice patterns of consumer and non-consumer mental health service providers. Community Ment Health J. Jun. 1999;35(3):251-69. Exclusion Code: X5. [pmid: 10401895].
262 Pearson CL, Locke G, Montgomery AE, et al. The Applicability of Housing First Models to Homeless Persons with Serious Mental Illness: Final Report. U.S. Department of Housing and Urban Development. Cambrdige, MA: Inc. AA. 2007. Exclusion Code: X2.
263 Phelan JC, Sinkewicz M, Castille DM, et al. Effectiveness and outcomes of assisted outpatient treatment in New York State. Psychiatr Serv. Feb. 2010;61(2):137-43. Exclusion Code: X2. [pmid: 20123818].
264 Piper WE, Rosic JS, Joyce AS, et al. Time limited day treatment for personality disorders. Psychotherapy research. 1997;7(3):317. Exclusion Code: X1.
265 Pirraglia PA, Kilbourne AM, Lai Z, et al. Colocated general medical care and preventable hospital admissions for veterans with serious mental illness. Psychiatr Serv. May. 2011;62(5):554-7. Exclusion Code: X2. [pmid: 21532086].
266 Pollack DA, McFarland BH, Mahler JM, et al. Outcomes of patients in a low-intensity, short-duration involuntary outpatient commitment program. Psychiatr Serv. Jul. 2005;56(7):863-6. Exclusion Code: X2. [pmid: 16020821].
267 Preston NJ, Kisely S, Xiao J. Assessing the outcome of compulsory psychiatric treatment in the community: epidemiological study in Western Australia. BMJ. May. 25. 2002;324(7348):1244. Exclusion Code: X2. [pmid: 12028977].
268 Priebe S, Jones G, McCabe R, et al. Effectiveness and costs of acute day hospital treatment compared with conventional in-patient care: randomised controlled trial (Structured abstract). Br J Psychiatry. 2006:243-9. Exclusion Code: X2. [pmid: 16507966].
269 Prince JD, Akincigil A, Kalay E, et al. Psychiatric rehospitalization among elderly persons in the United States. Psychiatr Serv. Sep. 2008;59(9):1038-45. Exclusion Code: X5. [pmid: 18757598].
270 Regenstein M, Andres E. Reducing hospital readmissions among Medicaid patients: a review of the literature. Qual Manag Health Care. 2014;23(1):20-42. Exclusion Code: X5. [pmid: 24368719].
271 Reilly S, Planner C, Gask L, et al. Collaborative care approaches for people with severe mental illness. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2013. Exclusion Code: X2.
272 Repper J, Carter T. A review of the literature on peer support in mental health services. J Ment Health. Aug. 2011;20(4):392-411. Exclusion Code: X2. [pmid: 21770786].
273 Reynolds W, Lauder W, Sharkey S, et al. The effects of a transitional discharge model for psychiatric patients. J Psychiatr Ment Health Nurs. 2004:82-8. Exclusion Code: X2. [pmid: 14723643].
274 Rogers ES, Teague GB, Lichenstein C, et al. Effects of participation in consumer-operated service programs on both personal and organizationally mediated empowerment: results of multisite study. J Rehabil Res Dev. 2007;44(6):785-99. Exclusion Code: X5. [pmid: 18075937].
275 Rohland BM. The role of outpatient commitment in the management of persons with schizophrenia. Iowa Consortium for Mental Health. Des Moines, IA. 1998. Exclusion Code: X5.
276 Rosen CS, Tiet QQ, Harris AH, et al. Telephone monitoring and support after discharge from residential PTSD treatment: a randomized controlled trial. Psychiatr Serv. Jan. 2013;64(1):13-20. Exclusion Code: X2. [pmid: 23117443].
277 Rosenberg G, Weissman A, Wong DFK. Clinical Case Management For People With Mental Illness: A Biopsychosocial Vulnerability-Stress Model. 1st ed. London. Routledge. 2014. Exclusion Code: X2.
278 Rossler W, Loffler W, Fatkenheuer B, et al. Does case management reduce the rehospitalization rate?. Acta Psychiatr Scand. Dec. 1992;86(6):445-9. Exclusion Code: X2. [pmid: 1471537].
279 Ruchlewska A, Mulder CL, Smulders R, et al. The effects of crisis plans for patients with psychotic and bipolar disorders: a randomised controlled trial. BMC Psychiatry. 2009;9:41. Exclusion Code: X3. [pmid: 19589145].
280 Rugkasa J, Dawson J. Community treatment orders: current evidence and the implications. Br J Psychiatry. Dec. 2013;203(6):406-8. Exclusion Code: X5. [pmid: 24297787].
281 Ryan T, Nambiar‐Greenwood G, Haigh C, et al. A service evaluation of a community‐based mental health crisis house in inner city Liverpool. Ment Health Rev J. 2011. 2011;16(2):56-63. Exclusion Code: X2.
282 Salib E, Iparragirre B. Detention of in-patients under section 5(2) of the Mental Health Act 1983. Med Sci Law. Jan. 1998;38(1):10-6. Exclusion Code: X3. [pmid: 9481073].
283 Salyers MP, Masterton TW, Fekete DM, et al. Transferring clients from intensive case management: impact on client functioning. Am J Orthopsychiatry. Apr. 1998;68(2):233-45. Exclusion Code: X5. [pmid: 9589761].
284 Salzer MS, Shear SL. Identifying consumer-provider benefits in evaluations of consumer-delivered services. Psychiatr Rehabil J. Winter. 2002;25(3):281-8. Exclusion Code: X2. [pmid: 11860001].
285 Sanborn C, editor. Case management in mental health services. New York. Routledge. 1983. Exclusion Code: X1.
286 Sande R, Rooijen L, Buskens E, et al. Intensive in-patient and community intervention versus routine care after attempted suicide. A randomised controlled intervention study. Br J Psychiatry. 1997:35-41. Exclusion Code: X2. [pmid: 9328492].
287 Savage R, Singh J, Bhoskar Suresh U, et al. Enhanced crisis planning for serious mental illness. Cochrane Database of Systematic Reviews. 2011;(12). Exclusion Code: X2.
288 Scheidcook TL. Controllers and controlled - an analysis of participant constructions of outpatient commitment. Sociol Health Illn. 1993;15(2):179-98. Exclusion Code: X6.
289 Schene AH. Partial hospitalization. Thornicroft G, Szmukler G, editors. Textbook of Community Psychiatry. Oxford, UK. Oxford University Press. 2001:283-94. Exclusion Code: X5.
290 Schene AH. The effectiveness of psychiatric partial hospitalization and day care. Curr Opin Psychiatr. 2004;17(4):303-9. Exclusion Code: X2.
291 Schene AH, van Wijngaarden B, Poelijoe NW, et al. The Utrecht comparative study on psychiatric day treatment and inpatient treatment. Acta Psychiatr Scand. Jun. 1993;87(6):427-36. Exclusion Code: X2. [pmid: 8356895].
292 Schutzwohl M, Jarosz-Nowak J, Briscoe J, et al. Inter-rater reliability of the Brief Psychiatric Rating Scale and the Groningen Social Disabilities Schedule in a European multi-site randomized controlled trial on the effectiveness of acute psychiatric day hospitals. Int J Methods Psychiatr Res. 2003;12(4):197-207. Exclusion Code: X5. [pmid: 14657976].
293 Schützwohl M, Koch R, Kallert TW. On the efficacy of acute psychiatric day-care treatment in a one-year-follow-up. A comparison to inpatient treatment within a randomised controlled trial. Psychiatr Prax. 2007:34-7. Exclusion Code: X1. [pmid: 17106839].
294 Scott G. Let’s start again with that emergency form. Nurs Stand. 2014. Sect. 3-. Exclusion Code: X5.
295 Scott JE, Dixon LB. Assertive community treatment and case management for schizophrenia. Schizophr Bull. 1995;21(4):657-68. Exclusion Code: X6. [pmid: 8749892].
296 Segal SP, Preston N, Kisely S, et al. Conditional release in Western Australia: effect on hospital length of stay. Psychiatr Serv. Jan. 2009;60(1):94-9. Exclusion Code: X2. [pmid: 19114577].
297 Segal SP, Silverman C, Temkin T. Characteristics and service use of long-term members of self-help agencies for mental health clients. Psychiatr Serv. Mar. 1995;46(3):269-74. Exclusion Code: X2. [pmid: 7796216].
298 Sellwood W, Thomas CS, Tarrier N, et al. A randomised controlled trial of home-based rehabilitation versus outpatient-based rehabilitation for patients suffering from chronic schizophrenia. Soc Psychiatry Psychiatr Epidemiol. 1999;34(5):250-3. Exclusion Code: X3. [pmid: 10396166].
299 Sharifi V, Tehranidoost M, Yunesian M, et al. Effectiveness of a low-intensity home-based aftercare for patients with severe mental disorders: a 12-month randomized controlled study. Community Ment Health J. Dec. 2012;48(6):766-70. Exclusion Code: X2. [pmid: 22772746].
300 Simpson A, Flood C, Rowe J, et al. Results of a pilot randomised controlled trial to measure the clinical and cost effectiveness of peer support in increasing hope and quality of life in mental health patients discharged from hospital in the UK. BMC Psychiatry. 2014;14(1):1-29. Exclusion Code: X2.
301 Simpson EL, House AO. Involving users in the delivery and evaluation of mental health services: systematic review. BMJ. Nov. 30. 2002;325(7375):1265. Exclusion Code: X2. [pmid: 12458241].
302 Slade M, Byford S, Barrett B, et al. Alternatives to standard acute in-patient care in England: short-term clinical outcomes and cost-effectiveness. Br J Psychiatry Suppl. Aug. 2010;53:s14-9. Exclusion Code: X2. [pmid: 20679274].
303 Sledge WH, Tebes J, Rakfeldt J, et al. Day hospital/crisis respite care versus inpatient care, Part I: Clinical outcomes. Am J Psychiatry. 1996:1065-73. Exclusion Code: X2. [pmid: 8678176].
304 Sledge WH, Tebes J, Wolff N, et al. Day hospital/crisis respite care versus inpatient care, Part II: Service utilization and costs. Am J Psychiatry. Aug. 1996;153(8):1074-83. Exclusion Code: X2. [pmid: 8678177].
305 Solomon P, Draine J. Satisfaction with mental health treatment in a randomized trial of consumer case management. J Nerv Ment Dis. Mar. 1994;182(3):179-84. Exclusion Code: X5. [pmid: 8113778].
306 Solomon P, Draine J. The efficacy of a consumer case management team: 2-year outcomes of a randomized trial. J Ment Health Adm. Spring. 1995;22(2):135-46. Exclusion Code: X2. [pmid: 10142127].
307 Solomon P, Draine J. One-year outcomes of a randomized trial of case management with seriously mentally ill clients leaving jail. Eval Rev. 1995;19:256-73. Exclusion Code: X5.
308 Solomon P, Draine J. One-Year Outcomes of a Randomized Trial of Consumer Case Management. Eval Program Plann. Apr 1995. 1995;18(2):117-27. Exclusion Code: X2.
309 Solomon P, Draine J. Service Delivery Differences between Consumer and Nonconsumer Case Managers in Mental Health. Research on Social Work Practice. Apr 1996. 1996;6(2):193-207. Exclusion Code: X5.
310 Solomon P, Draine J. Perspectives concerning consumers as case managers. Community Ment Health J. Feb. 1996;32(1):41-6. Exclusion Code: X5. [pmid: 8635316].
311 Starnino VR, Mariscal S, Holter MC, et al. Outcomes of an illness self-management group using wellness recovery action planning. Psychiatr Rehabil J. Summer. 2010;34(1):57-60. Exclusion Code: X2. [pmid: 20615846].
312 Stephens RJ, White SE, Cudnik M, et al. Factors associated with longer length of stay for mental health emergency department patients. J Emerg Med. Oct. 2014;47(4):412-9. Exclusion Code: X5. [pmid: 25074781].
313 Stevenson G. Detentions of older adults under the Mental Health (Care and Treatment) (Scotland) Act 2003. Med Sci Law. Jan. 2011;51(1):5-10. Exclusion Code: X5. [pmid: 21595414].
314 Stroup TS, Dorwart RA. Impact of a managed mental health program on Medicaid recipients with severe mental illness. Psychiatr Serv. Sep. 1995;46(9):885-9. Exclusion Code: X2. [pmid: 7583497].
315 Swanson JW, Swartz MS, Elbogen EB, et al. Effects of involuntary outpatient commitment on subjective quality of life in persons with severe mental illness. Behav Sci Law. 2003;21(4):473-91. Exclusion Code: X5. [pmid: 12898503].
316 Swanson JW, Van Dorn RA, Swartz MS, et al. Robbing Peter to pay Paul: did New York State's outpatient commitment program crowd out voluntary service recipients?. Psychiatr Serv. Oct. 2010;61(10):988-95. Exclusion Code: X5. [pmid: 20889636].
317 Swartz MS, Burns BJ, Hiday VA, et al. New directions in research on involuntary outpatient commitment. Psychiatr Serv. Apr. 1995;46(4):381-5. Exclusion Code: X2. [pmid: 7788461].
318 Swartz MS, Hiday VA, Swanson JW, et al. Measuring Coercion under Involuntary Outpatient Commitment: Initial Findings from a Randomized Controlled Trial. Research in community and mental health. 1999;10:57-77. Exclusion Code: X5.
319 Swartz MS, Swanson JW, Kim M, et al. Use of Outpatient Commitment or Related Civil Court Treatment Orders in Five U.S. Communities. Psychiatr Serv. Mar 2006. 2006;57(3):343-9. Exclusion Code: X2. [pmid: 16524991].
320 Swartz MS, Swanson JW, Wagner HR, et al. Effects of involuntary outpatient commitment and depot antipsychotics on treatment adherence in persons with severe mental illness. J Nerv Ment Dis. Sep. 2001;189(9):583-92. Exclusion Code: X5. [pmid: 11580001].
321 Swett C. Symptom severity and number of previous psychiatric admissions as predictors of readmission. Psychiatr Serv. May. 1995;46(5):482-5. Exclusion Code: X5. [pmid: 7627673].
322 Sytema S, Burgess P. Continuity of care and readmission in two service systems: a comparative Victorian and Groningen case-register study. Acta Psychiatr Scand. Sep. 1999;100(3):212-9. Exclusion Code: X2. [pmid: 10493088].
323 Sytema S, Micciolo R, Tansella M. Service utilization by schizophrenic patients in Groningen and South-Verona: an event-history analysis. Psychol Med. Jan. 1996;26(1):109-19. Exclusion Code: X3. [pmid: 8643750].
324 Sytema S, Micciolo R, Tansella M. Continuity of care for patients with schizophrenia and related disorders: a comparative south-Verona and Groningen case-register study. Psychol Med. Nov. 1997;27(6):1355-62. Exclusion Code: X2. [pmid: 9403907].
325 Tadros G, Salama RA, Kingston P, et al. Impact of an integrated rapid response psychiatric liaison team on quality improvement and cost savings: the Birmingham RAID model (Structured abstract). Psychiatrist. 2013:4-10. Exclusion Code: X2.
326 Telles C, Karno M, Mintz J, et al. Immigrant families coping with schizophrenia. Behavioral family intervention v. case management with a low-income Spanish-speaking population. Br J Psychiatry. Oct. 1995;167(4):473-9. Exclusion Code: X2. [pmid: 8829715].
327 Test M, Knoedler W, Allness D. Long term community care through an assertive continuous treatment team. Schizophr Res. (original pub year 1989). 1991;2(1–2):230. Exclusion Code: X1.
328 Thomas KA, Rickwood D. Clinical and cost-effectiveness of acute and subacute residential mental health services: a systematic review. Psychiatr Serv. Nov. 1. 2013;64(11):1140-9. Exclusion Code: X5. [pmid: 23903240].
329 Thomas MR, Dubovsky SL, Cox-Young B. Impact of external versus internal case managers on hospital utilization. Psychiatr Serv. Jun. 1996;47(6):593-5. Exclusion Code: X1. [pmid: 8726484].
330 Thomas MR, Rosenberg SA, Giese AA, et al. Shortening length of stay without increasing recidivism on a university-affiliated inpatient unit. Psychiatr Serv. Sep. 1996;47(9):996-8. Exclusion Code: X2. [pmid: 8875669].
331 Thompson EE, Neighbors HW, Munday C, et al. Length of stay, referral to aftercare, and rehospitalization among psychiatric inpatients. Psychiatr Serv. Sep. 2003;54(9):1271-6. Exclusion Code: X2. [pmid: 12954945].
332 Thornicroft G. A new mental health strategy for England. BMJ. 2011;342:d1346. Exclusion Code: X5. [pmid: 21372074].
333 Thornicroft G, Farrelly S, Birchwood M, et al. CRIMSON [CRisis plan IMpact: Subjective and Objective coercion and eNgagement] protocol: a randomised controlled trial of joint crisis plans to reduce compulsory treatment of people with psychosis. Trials. 2010;11:102. Exclusion Code: X3. [pmid: 21054847].
334 Thornicroft G, Farrelly S, Szmukler G, et al. Clinical outcomes of Joint Crisis Plans to reduce compulsory treatment for people with psychosis: a randomised controlled trial. Lancet. May. 11. 2013;381(9878):1634-41. Exclusion Code: X3. [pmid: 23537606].
335 Thornicroft G, Tansella M. What are the arguments for community based mental health care?. World Health Organization (European Region) Health Evidence Network. Copenhagen, Denmark. 2003. http://www.euro.who.int/__data/assets/pdf_file/0019/74710/E82976.pdf. Exclusion Code: X5.
336 Tomita A, Lukens EP, Herman DB. Mediation analysis of critical time intervention for persons living with serious mental illnesses: assessing the role of family relations in reducing psychiatric rehospitalization. Psychiatr Rehab J. 2014;37(1):4-10. Exclusion Code: X2.
337 Toprac MG, Holzer CE. Texas Crisis Alternatives Project: Cost-Effectiveness of 9 Crisis Residential Modalities: Final Report. Texas Department of Mental Health and Mental Retardation. TX. 1996. Exclusion Code: X2.
338 Trainor J, Shepherd M, Boydell KM, et al. Beyond the service paradigm: The impact and implications of consumer/survivor initiatives. Psychiatr Rehab J. Fal. 1997;21(2):132-40. PsycARTICLES Identifier: prj-21-2-132. First Author & Affiliation: Trainor, John. Exclusion Code: X2.
339 Trieman N, Smith HE, Kendal R, et al. The TAPS Project 41: homes for life? Residential stability five years after hospital discharge. Team for the Assessment of Psychiatric Services. Community Ment Health J. Aug. 1998;34(4):407-17. Exclusion Code: X3. [pmid: 9693869].
340 Tsemberis S, Gulcur L, Nakae M. Housing First, consumer choice, and harm reduction for homeless individuals with a dual diagnosis. Am J Public Health. Apr. 2004;94(4):651-6. Exclusion Code: X2. [pmid: 15054020].
341 Tucker S, Moore W, Luedtke C. Outcomes of a brief inpatient treatment program for mood and anxiety disorders. Outcomes Manag Nurs Pract. Jul-Sep. 2000;4(3):117-23. Exclusion Code: X2. [pmid: 11299580].
342 Tuohimaki C, Kaltiala-Heino R, Korkeila J, et al. Deprivation of liberty in Finnish psychiatric inpatients. Int J Law Psychiatry. Mar-Apr. 2004;27(2):193-205. Exclusion Code: X2. [pmid: 15063643].
343 Tyrer P, Evans K, Gandhi N, et al. Randomised controlled trial of two models of care for discharged psychiatric patients. BMJ. Jan. 10. 1998;316(7125):106-9. Exclusion Code: X2. [pmid: 9462315].
344 Tyrer P, Merson S, Onyett S, et al. The effect of personality disorder on clinical outcome, social networks and adjustment: a controlled clinical trial of psychiatric emergencies. Psychol Med. Aug. 1994;24(3):731-40. Exclusion Code: X2. [pmid: 7991755].
345 Valevski A, Olfson M, Weizman A, et al. Risk of readmission in compulsorily and voluntarily admitted patients. Soc Psychiatry Psychiatr Epidemiol. Nov. 2007;42(11):916-22. Exclusion Code: X3. [pmid: 17712501].
346 Välimäki M, Hätönen H, Lahti M, et al. Information and communication technology in patient education and support for people with schizophrenia. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012. Exclusion Code: X1.
347 Van Dorn RA, Swanson JW, Swartz MS, et al. Continuing medication and hospitalization outcomes after assisted outpatient treatment in New York. Psychiatr Serv. Oct. 2010;61(10):982-7. Exclusion Code: X7. [pmid: 20889635].
348 Wagner HR, Swartz MS, swanson JW, et al. Does involuntary outpatient commitment lead to more intensive treatment?. Psychol Public Policy Law. Mar-Jun. 2003;9(1-2):145-58. Exclusion Code: X2. [pmid: 16700140].
349 Wallsten T, Kjellin L, Lindstrom L. Short-term outcome of inpatient psychiatric care--impact of coercion and treatment characteristics. Soc Psychiatry Psychiatr Epidemiol. Dec. 2006;41(12):975-80. Exclusion Code: X3. [pmid: 17080321].
350 Warner R, Huxley P, Berg T. An evaluation of the impact of clubhouse membership on quality of life and treatment utilization. Int J Soc Psychiatry. Winter. 1999;45(4):310-20. Exclusion Code: X2. [pmid: 10689615].
351 Watkins KE, Pincus HA, Smith B, et al. Veterans Health Administration Mental Health Program Evaluation: Capstone Report. Altarum Institute and RAND Health. Affairs USDoV. 2011. Exclusion Code: X2.
352 Weidong J, Guoquan Z, Wenli F, et al. P02-292 - A randomized controlled trial on the efficacy of group psychoeducation family intervention for carers of persons with schizophrenia in shanghai. Eur Psychiatry. 2010;25:927. Exclusion Code: X2.
353 Wickizer TM, Lessler D. Do treatment restrictions imposed by utilization management increase the likelihood of readmission for psychiatric patients?. Med Care. Jun. 1998;36(6):844-50. Exclusion Code: X2. [pmid: 9630126].
354 Wiersma D, Kluiter H, Nienhuis FJ, et al. Costs and benefits of day treatment with community care for schizophrenic patients. Schizophr Bull. 1991;17(3):411-9. Exclusion Code: X2. [pmid: 1947866].
355 Wiersma D, Kluiter H, Nienhuis FJ, et al. Costs and benefits of hospital and day treatment with community care of affective and schizophrenic disorders. Br J Psychiatry Suppl. Apr. 1995;(27):52-9. Exclusion Code: X2. [pmid: 7794594].
356 Wijngaarden Bv, Ver Loren van Themaat-Hijmans M, Schene AH. Psychosocial rehabilitation in a clubhouse: an evaluation of nine years ‘de Waterheuvel’. Universiteit van Amsterdam/Stichting Fountain House Nederland. Amsterdam, The Netherlands. 1997. Exclusion Code: X1.
357 Yoshimasu K, Kiyohara C, Ohkuma K. Efficacy of day care treatment against readmission in patients with schizophrenia: A comparison between out-patients with and without day care treatment. Psychiatry Clin Neurosci. Aug. 2002;56(4):397-401. Exclusion Code: X2. [pmid: 12109957].
358 Ziguras SJ, Stuart GW. A meta-analysis of the effectiveness of mental health case management over 20 years (Structured abstract). Psychiatr Serv. 2000:1410-21. Exclusion Code: X2. [pmid: 11058189].