# Literature Strategy and Yields

PubMed Update Search with Revisions, 12/12/14

Limited to date range of 6/12/14 – present. Corrected search to add in the facilities terms, add “assertive community” keyword, broaden “Community Mental Health Services” term to not limit to “utilization” subheading, and adding in separate search for “home care services”. No study design limits. One record imported before de-duplication with existing records in database.

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search "Patient Admission"[Mesh] OR "Patient Discharge"[Mesh] OR "patient discharge"[All Fields] OR "discharge service"[All Fields] OR "discharge services"[All Fields] OR "Patient Readmission"[Mesh] OR "brief admission"[All Fields] OR "patient admission"[All Fields] OR readmission*[All Fields] OR "Commitment of Mentally Ill"[Mesh] | 56180 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Length of Stay”[Mesh] OR "length of stay"[All Fields] OR "Advance Directives"[Mesh] OR "advance directives"[All Fields] OR "Behavioral Medicine"[Mesh] OR "behavioral health"[All Fields] OR "Observation"[Mesh] OR "Case Management"[Mesh] OR "case management"[All Fields] OR "Crisis Intervention"[Mesh] OR "crisis intervention"[All Fields] OR "crisis residential service"[All Fields] OR "crisis residential services"[All Fields] OR psychoeducation[All Fields] OR "bridge visit"[All Fields] OR "bridge visits"[All Fields] OR "follow up call"[All Fields] OR "follow up calls"[All Fields] OR "conditional release"[All Fields] OR conservatorship[All Fields] OR "transitional services"[All Fields] OR "transitional care"[All Fields] OR "transition support services"[All Fields] OR "community treatment orders"[All Fields] OR "assertive community"[All Fields] OR "outpatient treatment"[All Fields] OR "out-patient treatment"[All Fields] OR "extended leave"[All Fields] OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR "Jurisprudence"[Mesh] OR "Mandatory Programs"[Mesh] OR "mandatory program"[All Fields] OR "mandatory programs"[All Fields] OR "supervised discharge"[All Fields] OR "mandated treatment"[All Fields] OR "forced treatment"[All Fields] OR "compulsory community treatment"[All Fields] OR "compulsory treatment"[All Fields] OR "extended leave"[All Fields] OR "community treatment order"[All Fields] OR "involuntary outpatient treatment"[All Fields] OR “involuntary medication”[All Fields] OR “forced medication”[All Fields] OR (“court-ordered"[All Fields] AND medication[All Fields]) OR “assisted outpatient treatment”[All Fields] OR "Aftercare"[Mesh] OR "predischarge intervention"[All Fields] OR "predischarge interventions"[All Fields] OR "assertive community"[All Fields] OR "home care services"[Mesh]) | 327926 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 21389 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Hospitals, Psychiatric"[Mesh] OR "Psychiatric Department, Hospital"[Mesh]) OR "Community Mental Health Services"[Majr] OR "psychiatric hospitalization"[All Fields] OR (psych* AND hospital*))) | 144736 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) | 4468 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Mentally Ill Persons"[Mesh] OR "Mental Disorders"[Mesh] OR “Diagnosis, Dual (Psychiatry)”[Mesh] OR "Psychotic Disorders"[Mesh] OR OR “Mentally ill”[All Fields] OR “seriously mentally ill”[All Fields] OR SMI[All Fields] OR SPMI[All Fields] OR “serious mental illness”[All Fields] OR “seriously and persistently mental ill”[All Fields] OR “severe mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental problems”[All Fields] OR “mental illness”[All Fields])) | 969038 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #6) | 8460 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) | 8757 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 AND #6 AND ("home care services"[Mesh])) | 561 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 or #9) | 9246 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 or #9) Filters: Humans | 9040 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 or #9) Filters: Humans; Adult: 19+ years | 4033 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 or #9) Filters: Publication date from 2014/06/12; Humans; Adult: 19+ years | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 or #9) Filters: Publication date from 2014/06/12; Humans; English; Adult: 19+ years | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)

PubMed Update Search with Revisions, 11/7/14

Limited to date range of 1/24/14 – present. Same revisions made to this search as to 12/12/14 search (see above). Corrected search to add in the facilities terms, add “assertive community” keyword, broaden “Community Mental Health Services” term to not limit to “utilization” subheading, and adding in separate search for “home care services”. No study design limits. 23 records imported before de-duplication with existing records in database.

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((("Patient Admission"[Mesh] OR "Patient Discharge"[Mesh] OR "patient discharge"[All Fields] OR "discharge service"[All Fields] OR "discharge services"[All Fields] OR "Patient Readmission"[Mesh] OR "brief admission"[All Fields] OR "patient admission"[All Fields] OR readmission*[All Fields] OR "Commitment of Mentally Ill"[Mesh] )) | 55912 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Length of Stay”[Mesh] OR "length of stay"[All Fields] OR "Advance Directives"[Mesh] OR "advance directives"[All Fields] OR "Behavioral Medicine"[Mesh] OR "behavioral health"[All Fields] OR "Observation"[Mesh] OR "Case Management"[Mesh] OR "case management"[All Fields] OR "Crisis Intervention"[Mesh] OR "crisis intervention"[All Fields] OR "crisis residential service"[All Fields] OR "crisis residential services"[All Fields] OR psychoeducation[All Fields] OR "bridge visit"[All Fields] OR "bridge visits"[All Fields] OR "follow up call"[All Fields] OR "follow up calls"[All Fields] OR "conditional release"[All Fields] OR conservatorship[All Fields] OR "transitional services"[All Fields] OR "transitional care"[All Fields] OR "transition support services"[All Fields] OR "community treatment orders"[All Fields] OR "assertive community"[All Fields] OR "outpatient treatment"[All Fields] OR "out-patient treatment"[All Fields] OR "extended leave"[All Fields] OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR "Jurisprudence"[Mesh] OR "Mandatory Programs"[Mesh] OR "mandatory program"[All Fields] OR "mandatory programs"[All Fields] OR "supervised discharge"[All Fields] OR "mandated treatment"[All Fields] OR "forced treatment"[All Fields] OR "compulsory community treatment"[All Fields] OR "compulsory treatment"[All Fields] OR "extended leave"[All Fields] OR "community treatment order"[All Fields] OR "involuntary outpatient treatment"[All Fields] OR “involuntary medication”[All Fields] OR “forced medication”[All Fields] OR (“court-ordered"[All Fields] AND medication[All Fields]) OR “assisted outpatient treatment”[All Fields] OR "Aftercare"[Mesh] OR "predischarge intervention"[All Fields] OR "predischarge interventions"[All Fields] OR "assertive community"[All Fields] OR "home care services"[Mesh]) | 327064 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) | 21300 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (("Hospitals, Psychiatric"[Mesh] OR "Psychiatric Department, Hospital"[Mesh]) OR "Community Mental Health Services"[Majr] OR "psychiatric hospitalization"[All Fields] OR (psych* AND hospital*))) | 143390 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #4) | 4461 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (("Mentally Ill Persons"[Mesh] OR "Mental Disorders"[Mesh] OR “Diagnosis, Dual (Psychiatry)”[Mesh] OR "Psychotic Disorders"[Mesh] OR OR “Mentally ill”[All Fields] OR “seriously mentally ill”[All Fields] OR SMI[All Fields] OR SPMI[All Fields] OR “serious mental illness”[All Fields] OR “seriously and persistently mental ill”[All Fields] OR “severe mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental problems”[All Fields] OR “mental illness”[All Fields])) | 967060 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #6) | 8451 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 or #7) | 8748 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 AND #6 AND ("home care services"[Mesh])) | 560 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 or #9) | 9236 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 or #9) Filters: Humans | 9032 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 or #9) Filters: Humans; Adult: 19+ years | 4028 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 or #9) Filters: Publication date from 2014/01/24; Humans; Adult: 19+ years | 31 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 or #9) Filters: Publication date from 2014/01/24; Humans; English; Adult: 19+ years | 23 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#13 NOT #14) | 8 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)

Additions (part 2) to PubMed Original Search, 11/7/14

Corrected search to include facilities terms that were accidentally not included in the final search from 6/24/14. 947 records imported before de-duplication with existing records in database.

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Patient Admission"[Mesh] OR "Patient Discharge"[Mesh] OR "patient discharge"[All Fields] OR "discharge service"[All Fields] OR "discharge services"[All Fields] OR "Patient Readmission"[Mesh] OR "brief admission"[All Fields] OR "patient admission"[All Fields] OR readmission*[All Fields] OR "Commitment of Mentally Ill"[Mesh] ) | 55912 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((“Length of Stay”[Mesh] OR "length of stay"[All Fields] OR "Advance Directives"[Mesh] OR "advance directives"[All Fields] OR "Behavioral Medicine"[Mesh] OR "behavioral health"[All Fields] OR "Observation"[Mesh] OR "Case Management"[Mesh] OR "case management"[All Fields] OR "Crisis Intervention"[Mesh] OR "crisis intervention"[All Fields] OR "crisis residential service"[All Fields] OR "crisis residential services"[All Fields] OR psychoeducation[All Fields] OR "bridge visit"[All Fields] OR "bridge visits"[All Fields] OR "follow up call"[All Fields] OR "follow up calls"[All Fields] OR "conditional release"[All Fields] OR conservatorship[All Fields] OR "transitional services"[All Fields] OR "transitional care"[All Fields] OR "transition support services"[All Fields] OR "community treatment orders"[All Fields] OR "assertive community treatment"[All Fields] OR "outpatient treatment"[All Fields] OR "out-patient treatment"[All Fields] OR "extended leave"[All Fields] OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR "Jurisprudence"[Mesh] OR "Mandatory Programs"[Mesh] OR "mandatory program"[All Fields] OR "mandatory programs"[All Fields] OR "supervised discharge"[All Fields] OR "mandated treatment"[All Fields] OR "forced treatment"[All Fields] OR "compulsory community treatment"[All Fields] OR "compulsory treatment"[All Fields] OR "extended leave"[All Fields] OR "community treatment order"[All Fields] OR "involuntary outpatient treatment"[All Fields] OR “involuntary medication”[All Fields] OR “forced medication”[All Fields] OR (“court-ordered"[All Fields] AND medication[All Fields]) OR “assisted outpatient treatment”[All Fields] OR "Aftercare"[Mesh] OR "predischarge intervention"[All Fields] OR "predischarge interventions"[All Fields] OR "assertive community"[All Fields] OR "home care services"[Mesh])))) | 327064 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 21300 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((("Hospitals, Psychiatric"[Mesh] OR "Psychiatric Department, Hospital"[Mesh]) OR "Community Mental Health Services/utilization"[Majr] OR "psychiatric hospitalization"[All Fields] OR (psych* and hospital*))))) | 29604 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) | 2143 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Mentally Ill Persons"[Mesh] OR "Mental Disorders"[Mesh] OR “Diagnosis, Dual (Psychiatry)”[Mesh] OR "Psychotic Disorders"[Mesh] OR OR “Mentally ill”[All Fields] OR “seriously mentally ill”[All Fields] OR SMI[All Fields] OR SPMI[All Fields] OR “serious mental illness”[All Fields] OR “seriously and persistently mental ill”[All Fields] OR “severe mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental problems”[All Fields] OR “mental illness”[All Fields]) | 967060 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #6) | 8451 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) | 8581 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) Filters: Humans | 8412 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) Filters: Humans; Adult: 19+ years | 3639 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) Filters: Publication date from 1990/01/01; Humans; Adult: 19+ years | 2790 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("review"[Publication Type] AND "systematic"[tiab]) OR "systematic review"[All Fields] OR ("review literature as topic"[MeSH] AND "systematic"[tiab]) OR "meta-analysis"[Publication Type] OR "meta-analysis as topic"[MeSH Terms] OR "meta-analysis"[All Fields])) | 136955 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 and #12) | 9 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH])) | 468314 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 and #14) | 141 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) Filters: Clinical Trial; Publication date from 1990/01/01; Humans; Adult: 19+ years | 241 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND (“prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | 165 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 and ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "Organizational Case Studies"[MeSH] OR "Cross-Over Studies"[MeSH])) | 917 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 or #15 or #16 or #17 or #18) | 1058 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 or #15 or #16 or #17 or #18) Filters: English | 947 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 not #20) | 111 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)

Additions (part 1) to PubMed Original Search, 11/7/14

Corrected search, adding facilities terms and then only searching specifically for comments, editorials, letters and news, which were also supposed to be included in the original search from 6/24/14 but were not. 57 records imported before de-duplication with existing records in database.

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Patient Admission"[Mesh] OR "Patient Discharge"[Mesh] OR "patient discharge"[All Fields] OR "discharge service"[All Fields] OR "discharge services"[All Fields] OR "Patient Readmission"[Mesh] OR "brief admission"[All Fields] OR "patient admission"[All Fields] OR readmission*[All Fields] OR "Commitment of Mentally Ill"[Mesh] ) | 55912 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((“Length of Stay”[Mesh] OR "length of stay"[All Fields] OR "Advance Directives"[Mesh] OR "advance directives"[All Fields] OR "Behavioral Medicine"[Mesh] OR "behavioral health"[All Fields] OR "Observation"[Mesh] OR "Case Management"[Mesh] OR "case management"[All Fields] OR "Crisis Intervention"[Mesh] OR "crisis intervention"[All Fields] OR "crisis residential service"[All Fields] OR "crisis residential services"[All Fields] OR psychoeducation[All Fields] OR "bridge visit"[All Fields] OR "bridge visits"[All Fields] OR "follow up call"[All Fields] OR "follow up calls"[All Fields] OR "conditional release"[All Fields] OR conservatorship[All Fields] OR "transitional services"[All Fields] OR "transitional care"[All Fields] OR "transition support services"[All Fields] OR "community treatment orders"[All Fields] OR "assertive community treatment"[All Fields] OR "outpatient treatment"[All Fields] OR "out-patient treatment"[All Fields] OR "extended leave"[All Fields] OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR "Jurisprudence"[Mesh] OR "Mandatory Programs"[Mesh] OR "mandatory program"[All Fields] OR "mandatory programs"[All Fields] OR "supervised discharge"[All Fields] OR "mandated treatment"[All Fields] OR "forced treatment"[All Fields] OR "compulsory community treatment"[All Fields] OR "compulsory treatment"[All Fields] OR "extended leave"[All Fields] OR "community treatment order"[All Fields] OR "involuntary outpatient treatment"[All Fields] OR “involuntary medication”[All Fields] OR “forced medication”[All Fields] OR (“court-ordered"[All Fields] AND medication[All Fields]) OR “assisted outpatient treatment”[All Fields] OR "Aftercare"[Mesh] OR "predischarge intervention"[All Fields] OR "predischarge interventions"[All Fields] OR "assertive community"[All Fields] OR "home care services"[Mesh])))) | 327064 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 21300 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((("Hospitals, Psychiatric"[Mesh] OR "Psychiatric Department, Hospital"[Mesh]) OR "Community Mental Health Services/utilization"[Majr] OR "psychiatric hospitalization"[All Fields] OR (psych* and hospital*))))) | 29604 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) | 2143 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Mentally Ill Persons"[Mesh] OR "Mental Disorders"[Mesh] OR “Diagnosis, Dual (Psychiatry)”[Mesh] OR "Psychotic Disorders"[Mesh] OR OR “Mentally ill”[All Fields] OR “seriously mentally ill”[All Fields] OR SMI[All Fields] OR SPMI[All Fields] OR “serious mental illness”[All Fields] OR “seriously and persistently mental ill”[All Fields] OR “severe mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental problems”[All Fields] OR “mental illness”[All Fields]) | 967060 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #6) | 8451 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) | 8581 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) Filters: Humans | 8412 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) Filters: Humans; Adult: 19+ years | 3639 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) Filters: Publication date from 1990/01/01; Humans; Adult: 19+ years | 2790 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("review"[Publication Type] AND "systematic"[tiab]) OR "systematic review"[All Fields] OR ("review literature as topic"[MeSH] AND "systematic"[tiab]) OR "meta-analysis"[Publication Type] OR "meta-analysis as topic"[MeSH Terms] OR "meta-analysis"[All Fields])) | 136955 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 and #12) | 9 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH])) | 468314 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 and #14) | 141 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #7) Filters: Clinical Trial; Publication date from 1990/01/01; Humans; Adult: 19+ years | 241 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND (“prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | 165 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 and ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "Organizational Case Studies"[MeSH] OR "Cross-Over Studies"[MeSH])) | 917 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 or #15 or #16 or #17 or #18) | 1058 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 or #15 or #16 or #17 or #18) Filters: English | 947 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 not #20) | 111 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt])) | 70 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#11 AND (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt])) Filters: English | 57 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#22 not #23) | 13 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)

PubMed Original Search, 6/24/14

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ("Patient Admission"[Mesh] OR "Patient Discharge"[Mesh] OR "patient discharge"[All Fields] OR "discharge service"[All Fields] OR "discharge services"[All Fields] OR "Patient Readmission"[Mesh] OR "brief admission"[All Fields] OR "patient admission"[All Fields] OR readmission*[All Fields]) | 49074 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Length of Stay”[Mesh] OR "length of stay"[All Fields] OR "Advance Directives"[Mesh] OR "advance directives"[All Fields] OR "Behavioral Medicine"[Mesh] OR "behavioral health"[All Fields] OR "Observation"[Mesh] OR "Case Management"[Mesh] OR "case management"[All Fields] OR "Crisis Intervention"[Mesh] OR "crisis intervention"[All Fields] OR "crisis residential service"[All Fields] OR "crisis residential services"[All Fields] OR psychoeducation[All Fields] OR "bridge visit"[All Fields] OR "bridge visits"[All Fields] OR "follow up call"[All Fields] OR "follow up calls"[All Fields] OR "conditional release"[All Fields] OR conservatorship[All Fields] OR "transitional services"[All Fields] OR "transitional care"[All Fields] OR "transition support services"[All Fields] OR "community treatment orders"[All Fields] OR "assertive community treatment"[All Fields] OR "outpatient treatment"[All Fields] OR "out-patient treatment"[All Fields] OR "extended leave"[All Fields] OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR "Jurisprudence"[Mesh] OR "Mandatory Programs"[Mesh] OR "mandatory program"[All Fields] OR "mandatory programs"[All Fields] OR "supervised discharge"[All Fields] OR "mandated treatment"[All Fields] OR "forced treatment"[All Fields] OR "compulsory community treatment"[All Fields] OR "compulsory treatment"[All Fields] OR "extended leave"[All Fields] OR "community treatment order"[All Fields] OR "involuntary outpatient treatment"[All Fields] OR “involuntary medication”[All Fields] OR “forced medication”[All Fields] OR (“court-ordered"[All Fields] AND medication[All Fields]) OR “assisted outpatient treatment”[All Fields]) | 279160 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) | 13058 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ("Hospitals, Psychiatric"[Mesh] OR "Psychiatric Department, Hospital"[Mesh]) OR "Community Mental Health Services/utilization"[Majr] OR "psychiatric hospitalization"[All Fields] OR (psych* and hospital*)) | 29410 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #4) | 1018 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ("Mentally Ill Persons"[Mesh] OR "Mental Disorders"[Mesh] OR “Diagnosis, Dual (Psychiatry)”[Mesh] OR "Substance-Related Disorders"[Mesh:NoExp] OR "Psychotic Disorders"[Mesh] OR “Behavior, Addictive”[Mesh] OR “Alcohol-Related Disorders”[Mesh] OR “Amphetamine-Related Disorders”[Mesh] OR “Cocaine-Related Disorders”[Mesh] OR “Inhalant Abuse”[Mesh] OR “Marijuana Abuse”[Mesh] OR “Opioid-Related Disorders”[Mesh] OR “Phencyclidine Abuse”[Mesh] OR “Substance Abuse, Intravenous”[Mesh] OR “Mentally ill”[All Fields] OR “seriously mentally ill”[All Fields] OR SMI[All Fields] OR SPMI[All Fields] OR “serious mental illness”[All Fields] OR “seriously and persistently mental ill”[All Fields] OR “severe mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental problems”[All Fields] OR “mental illness”[All Fields]) | 965286 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #6) | 2663 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 or #7) | 2778 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #6) Filters: Humans | 2646 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #6) Filters: Other Animals | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 not #9) | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 not #11) | 2646 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 not #11) Filters: Adult: 19+ years | 1741 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 not #11) Filters: Publication date from 1990/01/01 to 2014/12/31; Adult: 19+ years | 1455 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (("review"[Publication Type] AND "systematic"[tiab]) OR "systematic review"[All Fields] OR ("review literature as topic"[MeSH] AND "systematic"[tiab]) OR "meta-analysis"[Publication Type] OR "meta-analysis as topic"[MeSH Terms] OR "meta-analysis"[All Fields]) | 129116 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#14 and #15) | 6 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ("Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH]) | 458805 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #14 and #17 | 92 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 not #11) Filters: Clinical Trial; Publication date from 1990/01/01 to 2014/12/31; Adult: 19+ years | 152 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #14 AND (“prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) | 106 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #14 and ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "Organizational Case Studies"[MeSH] OR "Cross-Over Studies"[MeSH]) | 619 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#16 or #18 or #19 or #20 or #21) | 702 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#16 or #18 or #19 or #20 or #21) Filters: English | 637 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#22 NOT #23) Non-English | 65 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)

Cochrane Update Search with Revisions, 12/12/14

Limited to publication year of 2014. Corrected search to add the facilities terms, add an “assertive community” keyword, and add a separate search for “home care services”. No study design limits. 33 records imported before de-duplication with existing records in database.

ID | Search | Hits
#1 | [mh "Patient Admission"] or [mh "Patient Discharge"] or "patient discharge" or "discharge service" or "discharge services" or [mh "Patient Readmission"] or "brief admission" or "patient admission" or readmission* or [mh "Commitment of Mentally Ill"] | 4281
#2 | [mh "Length of Stay"] or "length of stay" or [mh "Advance Directives"] or "advance directives" or [mh "Behavioral Medicine"] or "behavioral health" or [mh Observation] or [mh "Case Management"] or "case management" or [mh "Crisis Intervention"] or "crisis intervention" or "crisis residential service" or "crisis residential services" or psychoeducation or "bridge visit" or "bridge visits" or "follow up call" or "follow up calls" or "conditional release" or conservatorship or "transitional services" or "transitional care" or "transition support services" or "community treatment orders" or "assertive community" or "outpatient treatment" or "out-patient treatment" or "extended leave" or ("commitment of mentally ill" and outpatient*) or (outpatient and commitment) or (involuntary and commitment) or [mh Jurisprudence] or [mh "Mandatory Programs"] or "mandatory program" or "mandatory programs" or "supervised discharge" or "mandated treatment" or "forced treatment" or "compulsory community treatment" or "compulsory treatment" or "extended leave" or "community treatment order" or "involuntary outpatient treatment" or "involuntary medication" or "forced medication" or ("court-ordered" and medication) or "assisted outpatient treatment" or [mh "home care services"] | 18563
#3 | #1 and #2 | 1821
#4 | [mh "Hospitals, Psychiatric"] or [mh "Psychiatric Department, Hospital"] or [mh "Community Mental Health Services" [mj]] or "psychiatric hospitalization" or (psych* and hospital*) | 20597
#5 | #3 and #4 | 462
#6 | [mh "Mentally Ill Persons"] or [mh "Mental Disorders"] or [mh "Diagnosis, Dual (Psychiatry)"] or [mh "Psychotic Disorders"] or "Mentally ill" or "seriously mentally ill" or SMI or SPMI or "serious mental illness" or "seriously and persistently mental ill" or "severe mental illness" or "mental disorders" or "mental problems" or "mental illness" | 45877
#7 | #3 and #6 | 291
#8 | #5 or #7 | 520
#9 | #5 or #7 Publication Year from 2014 to 2014 | 33

Cochrane Update Search with Revisions, 11/10/14

Limited to publication year of 2014. Same revisions made to this search strategy as to 12/12/14 search (see above). Corrected search to add the facilities terms, add an “assertive community” keyword, and add a separate search for “home care services”. No study design limits. 32 records imported before de-duplication with existing records in database.

ID | Search | Hits
#1 | [mh "Patient Admission"] or [mh "Patient Discharge"] or "patient discharge" or "discharge service" or "discharge services" or [mh "Patient Readmission"] or "brief admission" or "patient admission" or readmission* or [mh "Commitment of Mentally Ill"] | 4268
#2 | [mh "Length of Stay"] or "length of stay" or [mh "Advance Directives"] or "advance directives" or [mh "Behavioral Medicine"] or "behavioral health" or [mh Observation] or [mh "Case Management"] or "case management" or [mh "Crisis Intervention"] or "crisis intervention" or "crisis residential service" or "crisis residential services" or psychoeducation or "bridge visit" or "bridge visits" or "follow up call" or "follow up calls" or "conditional release" or conservatorship or "transitional services" or "transitional care" or "transition support services" or "community treatment orders" or "assertive community" or "outpatient treatment" or "out-patient treatment" or "extended leave" or ("commitment of mentally ill" and outpatient*) or (outpatient and commitment) or (involuntary and commitment) or [mh Jurisprudence] or [mh "Mandatory Programs"] or "mandatory program" or "mandatory programs" or "supervised discharge" or "mandated treatment" or "forced treatment" or "compulsory community treatment" or "compulsory treatment" or "extended leave" or "community treatment order" or "involuntary outpatient treatment" or "involuntary medication" or "forced medication" or ("court-ordered" and medication) or "assisted outpatient treatment" | 16648
#3 | #1 and #2 | 1652
#4 | [mh "Hospitals, Psychiatric"] or [mh "Psychiatric Department, Hospital"] or [mh "Community Mental Health Services" [mj]] or "psychiatric hospitalization" or (psych* and hospital*) | 20532
#5 | #3 and #4 | 436
#6 | [mh "Mentally Ill Persons"] or [mh "Mental Disorders"] or [mh "Diagnosis, Dual (Psychiatry)"] or [mh "Psychotic Disorders"] or "Mentally ill" or "seriously mentally ill" or SMI or SPMI or "serious mental illness" or "seriously and persistently mental ill" or "severe mental illness" or "mental disorders" or "mental problems" or "mental illness" | 45776
#7 | #3 and #6 | 282
#8 | #5 or #7 | 493
#9 | #5 or #7 Publication Year from 2014 to 2014 | 32
#10 | [mh "home care services"] | 2186
#11 | #1 and #10 | 314
#12 | #11 and (#4 or #6) | 77
#13 | #11 and (#4 or #6) Publication Year from 2014 to 2014 | 0

Cochrane Library Original Search, 6/23/14

ID | Search | Hits
#1 | [mh "Patient Admission"] or [mh "Patient Discharge"] or "patient discharge" or "discharge service" or "discharge services" or [mh "Patient Readmission"] or "brief admission" or "patient admission" or readmission* | 4027
#2 | [mh "Length of Stay"] or "length of stay" or [mh "Advance Directives"] or "advance directives" or [mh "Behavioral Medicine"] or "behavioral health" or [mh Observation] or [mh "Case Management"] or "case management" or [mh "Crisis Intervention"] or "crisis intervention" or "crisis residential service" or "crisis residential services" or psychoeducation or "bridge visit" or "bridge visits" or "follow up call" or "follow up calls" or "conditional release" or conservatorship or "transitional services" or "transitional care" or "transition support services" or "community treatment orders" or "assertive community treatment" or "outpatient treatment" or "out-patient treatment" or "extended leave" or ("commitment of mentally ill" and outpatient*) or (outpatient and commitment) or (involuntary and commitment) or [mh Jurisprudence] or [mh "Mandatory Programs"] or "mandatory program" or "mandatory programs" or "supervised discharge" or "mandated treatment" or "forced treatment" or "compulsory community treatment" or "compulsory treatment" or "extended leave" or "community treatment order" or "involuntary outpatient treatment" or "involuntary medication" or "forced medication" or ("court-ordered" and medication) or "assisted outpatient treatment" | 15915
#3 | #1 and #2 | 1526
#4 | [mh "Hospitals, Psychiatric"] or [mh "Psychiatric Department, Hospital"] or [mh "Community Mental Health Services" [mj]/UT] or "psychiatric hospitalization" or (psych* and hospital*) | 19509
#5 | #3 and #4 | 381
#6 | [mh "Mentally Ill Persons"] or [mh "Mental Disorders"] or [mh "Diagnosis, Dual (Psychiatry)"] or [mh ^"Substance-Related Disorders"] or [mh "Psychotic Disorders"] or [mh "Behavior, Addictive"] or [mh "Alcohol-Related Disorders"] or [mh "Amphetamine-Related Disorders"] or [mh "Cocaine-Related Disorders"] or [mh "Inhalant Abuse"] or [mh "Marijuana Abuse"] or [mh "Opioid-Related Disorders"] or [mh "Phencyclidine Abuse"] or [mh "Substance Abuse, Intravenous"] or "Mentally ill" or "seriously mentally ill" or SMI or SPMI or "serious mental illness" or "seriously and persistently mental ill" or "severe mental illness" or "mental disorders" or "mental problems" or "mental illness" | 45526
#7 | #3 and #6 | 228
#8 | #5 or #7 | 432

PsycInfo (EBSCO is vendor) Update Search, 12/12/14

Limited to 6/01/2014 – present. 12 of 13 results imported before de-duplication with existing records in database.

# | Query | Limiters/Expanders | Last Run Via | Results
S9 | S8 | Limiters - Published Date: 20140601-20141231; English; Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 13
S8 | S5 OR S7 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 672
S7 | S3 AND S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 211
S6 | DE "Homeless Mentally Ill" OR DE "Mentally Ill Offenders" OR "Mentally Ill Persons" OR DE "Mental Disorders" OR DE "Adjustment Disorders" OR DE "Affective Disorders" OR DE "Alexithymia" OR DE "Anxiety Disorders" OR DE "Autism" OR DE "Chronic Mental Illness" OR DE "Dementia" OR DE "Dissociative Disorders" OR DE "Eating Disorders" OR DE "Elective Mutism" OR DE "Factitious Disorders" OR DE "Gender Identity Disorder" OR DE "Hysteria" OR DE "Impulse Control Disorders" OR DE "Koro" OR DE "Mental Disorders due to General Medical Conditions" OR DE "Neurosis" OR DE "Paraphilias" OR DE "Personality Disorders" OR DE "Pervasive Developmental Disorders" OR DE "Pseudodementia" OR DE "Psychosis" OR DE "Schizoaffective Disorder" OR DE "Acute Psychosis" OR DE "Acute Schizophrenia" OR “Mentally ill” OR “seriously mentally ill” OR SMI OR SPMI OR “serious mental illness” OR “seriously and persistently mental ill” OR “severe mental illness” OR “mental disorders” OR “mental problems” OR “mental illness” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 242,529
S5 | S3 AND S4 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 651
S4 | DE "Psychiatric Hospitals" AND (psychiatric AND hospital AND department*) OR DE "Community Mental Health Services" OR DE "Community Counseling" OR "psychiatric hospitalization" OR (psych* and hospital*) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 210,013
S3 | S1 AND S2 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 931
S2 | DE "Treatment Duration" OR "treatment duration" OR "length of stay" OR DE "Advance Directives" OR "advance directives" OR DE "Behavioral Medicine" OR "behavioral health" OR DE "Case Management" OR "case management" OR DE "Crisis Intervention" OR DE "Debriefing (Psychological)" OR DE "Suicide Prevention" OR DE "Crisis Intervention Services" OR DE "Hot Line Services" OR DE "Suicide Prevention Centers" OR "crisis intervention" OR "crisis residential service" OR "crisis residential services" OR psychoeducation OR "bridge visit" OR "bridge visits" OR "follow up call" OR "follow up calls" OR "conditional release" OR conservatorship OR "transitional services" OR "transitional care" OR "transition support services" OR "community treatment orders" OR "assertive community" OR "outpatient treatment" OR "out-patient treatment" OR "extended leave" OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR DE "Law (Government)" OR DE "Civil Law" OR DE "Criminal Law" OR "mandatory program" OR "mandatory programs" OR "supervised discharge" OR "mandated treatment" OR "forced treatment" OR "compulsory community treatment" OR "compulsory treatment" OR "extended leave" OR "community treatment order" OR "involuntary outpatient treatment" OR “involuntary medication” OR “forced medication” OR (“court-ordered" AND medication) OR “assisted outpatient treatment” OR DE "Commitment (Psychiatric)" OR DE "Outpatient Commitment" OR DE "Home Care" | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 55,563
S1 | (DE "Hospital Admission") OR (DE "Discharge Planning") OR "patient discharge" OR "discharge service" OR "discharge services" OR [mh "Patient Readmission"] OR "brief admission" OR "patient admission" OR readmission* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4329

PsycInfo (EBSCO is vendor) Update Search, 11/10/14

Limited to 1/24/2014 – present. Same revisions made to this search as to 12/12/14 search (see above). One result retrieved but not imported into database because it was a duplicate with the above search strategies.

# | Query | Limiters/Expanders | Last Run Via | Results
S25 | S11 or S13 or S14 or S15 or S17 or S19 or S20 or S21 or S22 or S23 | Limiters - Published Date: 20140101-20141231 Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1
S24 | S11 or S13 or S14 or S15 or S17 or S19 or S20 or S21 or S22 or S23 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 46
S23 | S9 AND (evaluation AND stud*) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 42
S22 | S9 AND (comparative AND stud*) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 8
S21 | S9 AND news | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 0
S20 | S9 | Limiters - Document Type: Comment/Reply, Editorial, Erratum/Correction, Letter Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4
S19 | S9 AND S18 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 0
S18 | "Case-Control Studies" OR "Cohort Studies" OR "Organizational Case Studies" OR "Cross-Over Studies" | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,851
S17 | S9 AND S16 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 5
S16 | “prospective cohort” OR “prospective studies” OR (prospective* AND cohort) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 10,626
S15 | S9 | Limiters - Methodology: -Systematic Review Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 0
S14 | S9 | Limiters - Methodology: TREATMENT OUTCOME/CLINICAL TRIAL Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 34
S13 | S9 AND S12 | Limiters - Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 11
S12 | "Randomized Controlled Trial"OR "Single-Blind Method" OR "Double-Blind Method" OR DE "Random Sampling" OR "Random Allocation" | Limiters - Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 6,710
S11 | S9 AND S10 | Limiters - Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2
S10 | ("review" AND "systematic") OR "systematic review" OR ("review literature as topic" AND "systematic") OR "meta-analysis" OR "meta-analysis as topic" | Limiters - Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 5,578
S9 | S8 | Limiters - Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 446
S8 | S5 OR S7 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 666
S7 | S3 AND S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 208
S6 | DE "Homeless Mentally Ill" OR DE "Mentally Ill Offenders" OR "Mentally Ill Persons" OR DE "Mental Disorders" OR DE "Adjustment Disorders" OR DE "Affective Disorders" OR DE "Alexithymia" OR DE "Anxiety Disorders" OR DE "Autism" OR DE "Chronic Mental Illness" OR DE "Dementia" OR DE "Dissociative Disorders" OR DE "Eating Disorders" OR DE "Elective Mutism" OR DE "Factitious Disorders" OR DE "Gender Identity Disorder" OR DE "Hysteria" OR DE "Impulse Control Disorders" OR DE "Koro" OR DE "Mental Disorders due to General Medical Conditions" OR DE "Neurosis" OR DE "Paraphilias" OR DE "Personality Disorders" OR DE "Pervasive Developmental Disorders" OR DE "Pseudodementia" OR DE "Psychosis" OR DE "Schizoaffective Disorder" OR DE "Acute Psychosis" OR DE "Acute Schizophrenia" OR “Mentally ill” OR “seriously mentally ill” OR SMI OR SPMI OR “serious mental illness” OR “seriously and persistently mental ill” OR “severe mental illness” OR “mental disorders” OR “mental problems” OR “mental illness” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 241,161
S5 | S3 AND S4 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 645
S4 | DE "Psychiatric Hospitals" AND (psychiatric AND hospital AND department*) OR DE "Community Mental Health Services" OR DE "Community Counseling" OR "psychiatric hospitalization" OR (psych* and hospital*) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 208,354
S3 | S1 AND S2 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 924
S2 | DE "Treatment Duration" OR "treatment duration" OR "length of stay" OR DE "Advance Directives" OR "advance directives" OR DE "Behavioral Medicine" OR "behavioral health" OR DE "Case Management" OR "case management" OR DE "Crisis Intervention" OR DE "Debriefing (Psychological)" OR DE "Suicide Prevention" OR DE "Crisis Intervention Services" OR DE "Hot Line Services" OR DE "Suicide Prevention Centers" OR "crisis intervention" OR "crisis residential service" OR "crisis residential services" OR psychoeducation OR "bridge visit" OR "bridge visits" OR "follow up call" OR "follow up calls" OR "conditional release" OR conservatorship OR "transitional services" OR "transitional care" OR "transition support services" OR "community treatment orders" OR "assertive community" OR "outpatient treatment" OR "out-patient treatment" OR "extended leave" OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR DE "Law (Government)" OR DE "Civil Law" OR DE "Criminal Law" OR "mandatory program" OR "mandatory programs" OR "supervised discharge" OR "mandated treatment" OR "forced treatment" OR "compulsory community treatment" OR "compulsory treatment" OR "extended leave" OR "community treatment order" OR "involuntary outpatient treatment" OR “involuntary medication” OR “forced medication” OR (“court-ordered" AND medication) OR “assisted outpatient treatment” OR DE "Commitment (Psychiatric)" OR DE "Outpatient Commitment" OR DE "Home Care" | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 55,205
S1 | (DE "Hospital Admission") OR (DE "Discharge Planning") OR "patient discharge" OR "discharge service" OR "discharge services" OR [mh "Patient Readmission"] OR "brief admission" OR "patient admission" OR readmission* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,298

Additions (part 1) to PsycInfo (EBSCO is vendor) Original Search

Limited to 1990-present and search limited to editorials, letters, comments, news. Three records imported before de-duplication with existing records in database.

# | Query | Limiters/Expanders | Last Run Via | Results
S12 | S9 AND (S10 OR S11) | Limiters - Document Type: Editorial, Erratum/Correction, Letter Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3
S11 | news OR comment | Limiters - Document Type: Editorial, Erratum/Correction, Letter Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,057
S10 | | Limiters - Document Type: Editorial, Erratum/Correction, Letter Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 57,534
S9 | S8 | Limiters - Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 426
S8 | S5 OR S7 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 639
S7 | S3 AND S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 218
S6 | DE "Homeless Mentally Ill" OR DE "Mentally Ill Offenders" OR "Mentally Ill Persons" OR DE "Mental Disorders" OR DE "Adjustment Disorders" OR DE "Affective Disorders" OR DE "Alexithymia" OR DE "Anxiety Disorders" OR DE "Autism" OR DE "Chronic Mental Illness" OR DE "Dementia" OR DE "Dissociative Disorders" OR DE "Eating Disorders" OR DE "Elective Mutism" OR DE "Factitious Disorders" OR DE "Gender Identity Disorder" OR DE "Hysteria" OR DE "Impulse Control Disorders" OR DE "Koro" OR DE "Mental Disorders due to General Medical Conditions" OR DE "Neurosis" OR DE "Paraphilias" OR DE "Personality Disorders" OR DE "Pervasive Developmental Disorders" OR DE "Pseudodementia" OR DE "Psychosis" OR DE "Schizoaffective Disorder" OR "substance abuse disorders" OR DE "Drug Addiction" OR DE "Heroin Addiction" OR DE "Drug Dependency" OR DE "Acute Psychosis" OR DE "Acute Schizophrenia" OR DE "Addiction" OR DE "Alcoholism" OR DE "Drug Addiction" OR DE "Internet Addiction" OR DE "Sexual Addiction" OR "Amphetamine-Related Disorders" OR "Cocaine-Related Disorders" OR DE "Inhalant Abuse" OR DE "Glue Sniffing" OR "Marijuana Abuse" OR "Opioid-Related Disorders" OR "Phencyclidine Abuse" OR "intravenous substance abuse" OR “Mentally ill” OR “seriously mentally ill” OR SMI OR SPMI OR “serious mental illness” OR “seriously and persistently mental ill” OR “severe mental illness” OR “mental disorders” OR “mental problems” OR “mental illness” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 289,549
S5 | S3 AND S4 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 615
S4 | DE "Psychiatric Hospitals" AND (psychiatric AND hospital AND department*) OR DE "Community Mental Health Services" OR DE "Community Counseling" OR "psychiatric hospitalization" OR (psych* and hospital*) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 208,354
S3 | S1 AND S2 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 853
S2 | DE "Treatment Duration" OR "treatment duration" OR "length of stay" OR DE "Advance Directives" OR "advance directives" OR DE "Behavioral Medicine" OR "behavioral health" OR DE "Case Management" OR "case management" OR DE "Crisis Intervention" OR DE "Debriefing (Psychological)" OR DE "Suicide Prevention" OR DE "Crisis Intervention Services" OR DE "Hot Line Services" OR DE "Suicide Prevention Centers" OR "crisis intervention" OR "crisis residential service" OR "crisis residential services" OR psychoeducation OR "bridge visit" OR "bridge visits" OR "follow up call" OR "follow up calls" OR "conditional release" OR conservatorship OR "transitional services" OR "transitional care" OR "transition support services" OR "community treatment orders" OR "assertive community treatment" OR "outpatient treatment" OR "out-patient treatment" OR "extended leave" OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR DE "Law (Government)" OR DE "Civil Law" OR DE "Criminal Law" OR "mandatory program" OR "mandatory programs" OR "supervised discharge" OR "mandated treatment" OR "forced treatment" OR "compulsory community treatment" OR "compulsory treatment" OR "extended leave" OR "community treatment order" OR "involuntary outpatient treatment" OR “involuntary medication” OR “forced medication” OR (“court-ordered" AND medication) OR “assisted outpatient treatment” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 49,987
S1 | (DE "Hospital Admission") OR (DE "Discharge Planning") OR "patient discharge" OR "discharge service" OR "discharge services" OR [mh "Patient Readmission"] OR "brief admission" OR "patient admission" OR readmission* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,298

PsycINFO (EBSCO is vendor) Original Search, 6/23/14

# | Query | Limiters/Expanders | Last Run Via | Results
S21 | S11 OR S13 OR S15 OR S18 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 40
S20 | S9 AND S19 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 0
S19 | "Case-Control Studies" OR "Cohort Studies" OR "Organizational Case Studies" OR "Cross-Over Studies" | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,729
S18 | S9 AND S17 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3
S17 | “prospective cohort” OR “prospective studies” OR (prospective* AND cohort) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 10,073
S16 | S9 | Limiters - Methodology: -Systematic Review Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 0
S15 | S9 AND S14 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 33
S14 | | Limiters - Methodology: TREATMENT OUTCOME/CLINICAL TRIAL Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 27,136
S13 | S9 AND S12 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 11
S12 | "Randomized Controlled Trial"OR "Single-Blind Method" OR "Double-Blind Method" OR DE "Random Sampling" OR "Random Allocation" | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 9,227
S11 | S9 AND S10 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2
S10 | ("review" AND "systematic") OR "systematic review" OR ("review literature as topic" AND "systematic") OR "meta-analysis" OR "meta-analysis as topic" | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 30,391
S9 | S8 | Limiters - Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 413
S8 | S5 OR S7 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 623
S7 | S3 AND S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 213
S6 | DE "Homeless Mentally Ill" OR DE "Mentally Ill Offenders" OR "Mentally Ill Persons" OR DE "Mental Disorders" OR DE "Adjustment Disorders" OR DE "Affective Disorders" OR DE "Alexithymia" OR DE "Anxiety Disorders" OR DE "Autism" OR DE "Chronic Mental Illness" OR DE "Dementia" OR DE "Dissociative Disorders" OR DE "Eating Disorders" OR DE "Elective Mutism" OR DE "Factitious Disorders" OR DE "Gender Identity Disorder" OR DE "Hysteria" OR DE "Impulse Control Disorders" OR DE "Koro" OR DE "Mental Disorders due to General Medical Conditions" OR DE "Neurosis" OR DE "Paraphilias" OR DE "Personality Disorders" OR DE "Pervasive Developmental Disorders" OR DE "Pseudodementia" OR DE "Psychosis" OR DE "Schizoaffective Disorder" OR "substance abuse disorders" OR DE "Drug Addiction" OR DE "Heroin Addiction" OR DE "Drug Dependency" OR DE "Acute Psychosis" OR DE "Acute Schizophrenia" OR DE "Addiction" OR DE "Alcoholism" OR DE "Drug Addiction" OR DE "Internet Addiction" OR DE "Sexual Addiction" OR "Amphetamine-Related Disorders" OR "Cocaine-Related Disorders" OR DE "Inhalant Abuse" OR DE "Glue Sniffing" OR "Marijuana Abuse" OR "Opioid-Related Disorders" OR "Phencyclidine Abuse" OR "intravenous substance abuse" OR “Mentally ill” OR “seriously mentally ill” OR SMI OR SPMI OR “serious mental illness” OR “seriously and persistently mental ill” OR “severe mental illness” OR “mental disorders” OR “mental problems” OR “mental illness” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 282,250
S5 | S3 AND S4 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 599
S4 | DE "Psychiatric Hospitals" AND (psychiatric AND hospital AND department*) OR DE "Community Mental Health Services" OR DE "Community Counseling" OR "psychiatric hospitalization" OR (psych* and hospital*) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 201,469
S3 | S1 AND S2 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 829
S2 | DE "Treatment Duration" OR "treatment duration" OR "length of stay" OR DE "Advance Directives" OR "advance directives" OR DE "Behavioral Medicine" OR "behavioral health" OR DE "Case Management" OR "case management" OR DE "Crisis Intervention" OR DE "Debriefing (Psychological)" OR DE "Suicide Prevention" OR DE "Crisis Intervention Services" OR DE "Hot Line Services" OR DE "Suicide Prevention Centers" OR "crisis intervention" OR "crisis residential service" OR "crisis residential services" OR psychoeducation OR "bridge visit" OR "bridge visits" OR "follow up call" OR "follow up calls" OR "conditional release" OR conservatorship OR "transitional services" OR "transitional care" OR "transition support services" OR "community treatment orders" OR "assertive community treatment" OR "outpatient treatment" OR "out-patient treatment" OR "extended leave" OR ("commitment of mentally ill" AND outpatient*) OR (outpatient AND commitment) OR (involuntary AND commitment) OR DE "Law (Government)" OR DE "Civil Law" OR DE "Criminal Law" OR "mandatory program" OR "mandatory programs" OR "supervised discharge" OR "mandated treatment" OR "forced treatment" OR "compulsory community treatment" OR "compulsory treatment" OR "extended leave" OR "community treatment order" OR "involuntary outpatient treatment" OR “involuntary medication” OR “forced medication” OR (“court-ordered" AND medication) OR “assisted outpatient treatment” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 48,608
S1 | (DE "Hospital Admission") OR (DE "Discharge Planning") OR "patient discharge" OR "discharge service" OR "discharge services" OR [mh "Patient Readmission"] OR "brief admission" OR "patient admission" OR readmission* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,184

#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ("Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH]) | 458205 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#13 and #16) | 101 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#9 not #11) Filters: Clinical Trial; Adult: 19+ years | 162 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#13 and (“prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | 111 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#13 and ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "Organizational Case Studies"[MeSH] OR "Cross-Over Studies"[MeSH])) | 702 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 or #17 or #18 or #19 or #20) | 790 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 or #17 or #18 or #19) | 258 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 or #17 or #18 or #19) Filters: English | 241 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 or #17 or #18 or #19 or #20) Filters: English SAVED | 717 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#21 NOT #24) NON-ENGLISH SAVED SEPARATELY | 73 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)