# Key Informant Interview and Literature Search Methodology

## Key Informant Interview Methodology

We adhered to the Office of Management and Budget (OMB) requirements and limited standardized questions (the list of Guiding Questions [GQs]) to no more than 9 nongovernment-associated individuals. As a result, we did not need to obtain OMB clearance for the interviews.

After review and approval of the completed Disclosure Forms for Conflicts of Interest for the proposed Key Informants (KIs) by the Agency for Healthcare and Quality (AHRQ), we conducted interviews with eight selected KIs, five on one call and three on another. The interviews were a combination of individual KIs based on availability and concordance of perspectives. The Principal Investigator from the Evidence-based Practice Center (EPC) team for this Technical Brief led each of the KI interviews, and the Task Order Officer (TOO) was in attendance for both discussions, along with other EPC team members who would be authors on the Technical Brief. The recorded KI interviews were 1.5 hours each. Following each interview, we summarized the interviews in writing by incorporating summary notes prepared by team members; professional transcriptions of the interview; and if necessary referring back to the actual recordings. We then submitted summary notes to the TOO for documentation. We generated a summary of findings from both KI discussions, organized by subquestion for authors’ use in the integrated analysis for each guiding question section in the report. Authors identified any unique perspectives from KIs that were not part of the literature review findings.

## Literature Search Methodology

Sources for the gray literature include the following:

- HAPI: Health and Psychosocial Instruments provides bibliographic access and descriptions of tests, manuals, rating scales, and other instruments used to assess health and behavior. They assist researchers and others in locating instruments used in the health fields, psychosocial sciences, occupational sciences, library and information science, and education.
- OpenSIGLE: Operated by GreyNet, the OpenSIGLE Repository preserves and makes openly accessible research results originating in the International Conference Series on Grey Literature. GreyNet together with the Institute for Scientific and Technical Information-National Center for Scientific Research designed the format for a metadata record, which encompasses standardized PDF attachments for full-text conference preprints, PowerPoint presentations, abstracts, and biographical notes. All 11 volumes (1993–2009) of the GL Conference Proceedings are available in the OpenSIGLE Repository.
- ClinicalTrials.gov: ClinicalTrials.gov offers up-to-date information for locating federally and privately supported clinical trials for a wide range of diseases and conditions. The site currently contains approximately 12,400 clinical studies sponsored by the National Institutes of Health, other federal agencies, and private industry. Studies listed in the database are conducted in all 50 States and in more than 100 countries.
- WHO International Clinical Trials Registry Platform: This platform is a network of international clinical trials registers to ensure a single point of access and the unambiguous identification of trials.
- Academic Search Complete: This source provides information from a wide range of academic areas, including business, social sciences, humanities, general academic, general science, education, and multicultural topics. This multidisciplinary database features full text for more than 4,000 journals with many dating back to 1975, abstracts and indexing for more than 8,200 scholarly journals, and coverage of selected newspapers and other news sources.
- NIH RePORTER: The information found in RePORTER is drawn from several extant databases (eRA databases, Medline®, PubMed Central, the NIH Intramural Database, and iEdison), using newly formed linkages among these disparate data sources.

We also searched Web sites of the relevant professional associations such as the American Psychiatric Association, the National Alliance on Mental Illness, the National Association of Psychiatric Health Systems, and the National Institute of Mental Health.