# Summary and Implications

There is expert consensus in the literature that EHRs used in the care of children require specific pediatric functionalities to support the work of child health care providers and to assure the delivery of quality care to pediatrics patients. These functionalities relate to a child's evolving physiology and maturity and the conditions that are associated with those.77,78 Key areas include vaccination, child development, physiologic medication dosing, pediatric disease management, pediatric norms, and the relationship between pediatric patients and their caregivers, including adolescent privacy.

Vaccine forecasting and management is generally considered a critical pediatric functionality of an EHR. Forecasting is complex and must reflect local and regional immunization requirements. It must support documentation and appropriate handling of combination vaccinations. In accordance with meaningful use requirements and to support the pediatric clinician, the EHR must have the ability to communicate with one or more vaccine registries and exchange data bidirectionally.

The EHR needs functionalities to support longitudinal assessment of child growth and development and counseling regarding injury prevention, proper nutrition, and lifestyle choices. Bright Futures is the primary guideline used by most pediatric clinicians for child development and growth as well as screening for abnormalities and anticipatory guidance.62 The EHR could maximally support child development recommendations by providing tailored longitudinal recommendations for individual patients using clinical decision support, such as those from Bright Futures.63,65 A key functionality related to the child's changing physiology and maturity is the incorporation of pediatric specific norms and growth charts into the EHR. A pediatric provider must assure adequate, on-target growth and development. This work requires the EHR to support longitudinal documentation of growth and developmental patterns with adequate age and granularity specifications. The growth chart should be readily available in the EHR and must capture weight, height or length, head circumference and calculate body mass index, growth velocity, percentiles and standard deviations based on population norms. Display should be available in a variety of formats that vary based on gender and condition (e.g. trisomy 21). The growth chart should support adjustments for gestational age, mid-parental height, bone age measurements, and the ability to manipulate, display, or disseminate data in a variety of ways to suit the clinician's needs.

Clinicians often describe EHRs as complex and cumbersome to use. An optimal EHR is created according to user-centered design principles to support workflow and reduce documentation workload. Data is assimilated from multiple sources and is readily available for the pediatric provider. The EHR should be flexible enough to support capture and generation of screening forms and health summaries for secondary use of medical data, such as with school or athletic forms.

A pediatric friendly EHR must support medication dosing based on dynamic physiological parameters such as weight, age, body surface area, and metabolic function. Medication ordering is additionally complicated by a wide array of available tablet strengths and liquid concentrations. The appropriate dose and medication interactions can also change by the route of administration. EHRs should facilitate weight and body-surface based dosing that supports appropriate rounding based on a medication's safety and efficacy margin, which may change based on route and patient's physiology such as hepatic or renal function. Prescribing should also incorporate common features of adult medication management such as drug-drug and drug-allergy checking, provision of an indication and diagnosis associated with each medication, and the ability to provide comments with salient prescription information that should be made available to pharmacists and others downstream. In summary, the EHR prescribing system should provide assistance in selecting appropriate dose and dispensing amounts given the specific patient's physiology and maturity and diagnoses.

The pediatric EHR should support functionality that assists with care and management of common pediatric conditions, such as asthma, attention deficit hyperactivity disorder, and perinatal exposures. On the macro scale, the EHR should support management of clinical subpopulations by allowing creation of customized lists based on condition or feature. On the individual scale, the EHR incorporate clinical practice guidelines and recommendations into the standard clinical workflow, including generation of pediatric specific billing codes and documentation.

A key functionality related to the child's changing physiology and maturity is the incorporation of pediatric specific norms and growth charts into the EHR. A pediatric provider must assure adequate, on-target growth and development. This work requires the EHR to support longitudinal documentation of growth and developmental patterns with adequate age and granularity specifications. The growth chart should be readily available in the EHR and must capture weight, height or length, head circumference and calculate body mass index, growth velocity, percentiles and standard deviations based on population norms. Display should be available in a variety of formats that vary based on gender and condition (e.g. trisomy 21). The growth chart should support adjustments for gestational age, mid-parental height, bone age measurements, and the ability to manipulate, display, or disseminate data in a variety of ways to suit the clinician's needs.

The pediatric patient is cared for in the context of a dynamic family and social structure. For the young child, this includes linking complex family structures and promoting anticipatory guidance and screening that is tailored to the individual in the context of that structure. As the child becomes an adolescent, the EHR must support robust privacy controls that may have many complexities. Reports in the literature and Key Informants advocate default privacy functionality that can then be customized to allow differential access to various portions of the adolescent electronic health record. Such privacy settings must be in accordance with State laws that require confidentiality. With granularity and customizability, a successful implementation has the potential to provide even more security than classical paper records and may allow clinicians to better care for the unique needs of the adolescent patient population.67

While many of these functionalities are not purely pediatric, their key role in the care of children in contrast to their minimal role for adults could mean they can get overlooked if an EHR is designed primarily for adult care.48,60 Yet, if these functionalities are implemented well, the EHR will also undoubtedly better support the care of all patients (Table 10).

Table 10 Summary and Implications

Core Functionalities in Pediatric Electronic Health Records
Vaccine forecasting and management; - Reflects regional requirements; - Supports documentation, including combination vaccinations; - Communicates with registries
Routine Health Care Maintenance; - Facilitates longitudinal assessment of growth and development; - Calculates body mass index, growth velocity, percentiles, and standard deviations; - Allows customized growth charts as approved by clinician; - Provides tailored longitudinal health and safety recommendations
Documentation and Billing; - Integrates into a clinician's workflow to reduce documentation overload; - Supports use and creation of customized forms; - Interfaces with schools and community health organizations
Medications; - Facilitates medication prescribing by weight, body surface area, and age; - Incorporates dose rounding tailored to a medication's safety and efficacy profile
Management of Vulnerable Populations; - Generates patient lists based on key clinical diagnoses or risk factors; - Identifies patients in a clinical subpopulation who are due for preventative services; - Incorporates clinical practice guidelines into a standard clinical workflow
Family Structures; - Links families together for easy navigation and data sharing between family members; - Supports dynamic privacy controls that support differential access to health data

A number of challenges were identified in the technical brief. For example, vaccine functionality in EHRs is hindered by factors such as non-centralized, proprietary databases that cause fragmentation of vaccination records. Clinical decision support does not perform well when documentation is incomplete and in fact can prompt physicians to give immunizations unnecessarily. Thus, finding ways to ensure that various databases communicate well and that one complete and correct record is available are particular challenges to properly implementing vaccination procedures in the EHR. In terms of medication management, enhancing an adult-focused CPOE system for a safe pediatric medication management is an intense and sophisticated task and has limitations.110 Such efforts require high-level sponsorship, involvement of clinicians, and round-the-clock support.111 Routine health care maintenance is a particularly challenging area of general pediatrics. The AAP has approved nine different developmental screening instruments – all of which vary in format, sensitivity, specificity, and modality. Bright Futures, the most commonly used reference for routine health care maintenance, has proven difficult to incorporate actively into electronic health records due to only a minority of recommendations being computationally decidable and executable.65 Tracking growth in children adds yet other challenges. Both the Centers for Disease Control and the World Health Organization have published validated standard growth charts for boys and girls. Unfortunately, validated charts do not exist for many diseases, despite these being highly desired by pediatric providers. This creates a challenge for EHR venders who must choose either to including non-validated charts in their software, to rely on customers to decide which charts they will support, or not to include alternates at all.89-91

Our Technical Brief does have limitations. It is not intended to be complete systematic review; nor were we able to include the viewpoints of a wider range of Key Informants. Only one vendor is represented, for example. Nonetheless, it does provide an overview of the current state of the science; it was also available for public comment for 4 weeks and we have responded to those comments and incorporated additional perspectives in that way.