# References

1 Policy Statement--Using personal health records to improve the quality of health care for children. Pediatrics. Jul. 2009;124(1):403-9. [pmid: 19564327].
2 Shiffman RN, Spooner SA, Kwiatkowski K, et al. Information technology for children's health and health care: report on the Information Technology in Children's Health Care Expert Meeting, September 21-22, 2000. J Am Med Inform Assoc. Nov-Dec. 2001;8(6):546-51. [pmid: 11687562].
3 Kim GR, Lehmann CU. Pediatric aspects of inpatient health information technology systems. Pediatrics. Dec. 2008;122(6):e1287-96. [pmid: 19047228].
4 Lehmann CU, Kim GR, Gujral R, et al. Decreasing errors in pediatric continuous intravenous infusions. Pediatr Crit Care Med. May. 2006;7(3):225-30. [pmid: 16575355].
5 Lehmann CU, Kim GR. Computerized provider order entry and patient safety. Pediatr Clin North Am. Dec. 2006;53(6):1169-84. [pmid: 17126689].
6 Kim GR, Lawson EE, Lehmann CU. Challenges in reusing transactional data for daily documentation in neonatal intensive care. AMIA Annu Symp Proc. 2008;1009. [pmid: 18998993].
7 Kim GR, Chen AR, Arceci RJ, et al. Error reduction in pediatric chemotherapy: computerized order entry and failure modes and effects analysis. Arch Pediatr Adolesc Med. May. 2006;160(5):495-8. [pmid: 16651491].
8 Bundy DG, Persing NM, Solomon BS, et al. Improving immunization delivery using an electronic health record: the ImmProve project. Acad Pediatr. Sep-Oct. 2013;13(5):458-65. [pmid: 23726754].
9 Simpson RL. Neither seen nor heard: why we need a child-friendly electronic health record. Nurs Adm Q. Jan-Mar. 2009;33(1):78-83. [pmid: 19092530].
10 Kemper AR, Uren RL, Clark SJ. Adoption of electronic health records in primary care pediatric practices. Pediatrics. Jul. 2006;118(1):e20-4. [pmid: 16818534].
11 Gracy D, Weisman J, Grant R, et al. Content barriers to pediatric uptake of electronic health records. Adv Pediatr. 2012;59(1):159-81. [pmid: 22789578].
12 Han YY, Carcillo JA, Venkataraman ST, et al. Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system. Pediatrics. Dec. 2005;116(6):1506-12. [pmid: 16322178].
13 Kirkendall ES, Spooner SA, Logan JR. Evaluating the accuracy of electronic pediatric drug dosing rules. J Am Med Inform Assoc. Feb. 2014;21(e1):e43-9. [pmid: 23813541].
14 D'Agostino JA, Gerdes M, Hoffman C, et al. Provider use of corrected age during health supervision visits for premature infants. J Pediatr Health Care. May-Jun. 2013;27(3):172-9. [pmid: 23611457].
15 Stultz JS, Nahata MC. Appropriateness of commercially available and partially customized medication dosing alerts among pediatric patients. J Am Med Inform Assoc. Feb. 2014;21(e1):e35-42. [pmid: 23813540].
16 Fiks AG, Grundmeier RW, Biggs LM, et al. Impact of clinical alerts within an electronic health record on routine childhood immunization in an urban pediatric population. Pediatrics. Oct. 2007;120(4):707-14. [pmid: 17908756].
17 Fiks AG, Hunter KF, Localio AR, et al. Impact of electronic health record-based alerts on influenza vaccination for children with asthma. Pediatrics. Jul. 2009;124(1):159-69. [pmid: 19564296].
18 Co JP, Johnson SA, Poon EG, et al. Electronic health record decision support and quality of care for children with ADHD. Pediatrics. Aug. 2010;126(2):239-46. [pmid: 20643719].
19 Rand CM, Blumkin A, Szilagyi PG. Electronic health record use and preventive counseling for US children and adolescents. J Am Med Inform Assoc. Feb. 2014;21(e1):e152-6. [pmid: 24013091].
20 Adams WG, Mann AM, Bauchner H. Use of an electronic medical record improves the quality of urban pediatric primary care. Pediatrics. Mar. 2003;111(3):626-32. [pmid: 12612247].
21 Abughali N, Maxwell JR, Kamath AS, et al. Interventions using electronic medical records improve follow up of infants born to hepatitis C virus infected mothers. Pediatr Infect Dis J. Apr. 2014;33(4):376-80. [pmid: 24401869].
22 Gray SH, Pasternak RH, Gooding HC, et al. Recommendations for electronic health record use for delivery of adolescent health care. J Adolesc Health. Apr. 2014;54(4):487-90. [pmid: 24656534].
23 Levine LD, Chang J, Merkatz IR, et al. Enhanced physician prompts in prenatal electronic medical records impact documentation on smoking cessation. Open J Obstet Gynecol. Dec. 1. 2013;3(10):717-21. [pmid: 24653945].
24 Babbott S, Manwell LB, Brown R, et al. Electronic medical records and physician stress in primary care: results from the MEMO Study. J Am Med Inform Assoc. Feb. 2014;21(e1):e100-6. [pmid: 24005796].
25 Featherstone I, Keen J. Do integrated record systems lead to integrated services? An observational study of a multi-professional system in a diabetes service. Int J Med Inform. Jan. 2012;81(1):45-52. [pmid: 21962435].
26 Petroll AE, Phelps JK, Fletcher KE. Implementation of an electronic medical record does not change delivery of preventive care for HIV-positive patients. Int J Med Inform. Apr. 2014;83(4):273-7. [pmid: 24440204].
27 Imperiale TF, Sherer EA, Balph JA, et al. Provider acceptance, safety, and effectiveness of a computer-based decision tool for colonoscopy preparation. Int J Med Inform. Oct. 2011;80(10):726-33. [pmid: 21920302].
28 Poon EG, Wright A, Simon SR, et al. Relationship between use of electronic health record features and health care quality: results of a statewide survey. Med Care. Mar. 2010;48(3):203-9. [pmid: 20125047].
29 Lau F, Kuziemsky C, Price M, et al. A review on systematic reviews of health information system studies. J Am Med Inform Assoc. Nov-Dec. 2010;17(6):637-45. [pmid: 20962125].
30 Romano MJ, Stafford RS. Electronic health records and clinical decision support systems: impact on national ambulatory care quality. Arch Intern Med. May. 23. 2011;171(10):897-903. [pmid: 21263077].
31 Walsh MN, Yancy CW, Albert NM, et al. Electronic health records and quality of care for heart failure. Am Heart J. Apr. 2010;159(4):635-42.e1. [pmid: 20362723].
32 Holroyd-Leduc JM, Lorenzetti D, Straus SE, et al. The impact of the electronic medical record on structure, process, and outcomes within primary care: a systematic review of the evidence. J Am Med Inform Assoc. Nov-Dec. 2011;18(6):732-7. [pmid: 21659445].
33 Linder JA, Ma J, Bates DW, et al. Electronic health record use and the quality of ambulatory care in the United States. Arch Intern Med. Jul. 9. 2007;167(13):1400-5. [pmid: 17620534].
34 Herrin J, da Graca B, Aponte P, et al. Impact of an EHR-Based Diabetes Management Form on Quality and Outcomes of Diabetes Care in Primary Care Practices. Am J Med Qual. 2014. Jan. 7. [pmid: 24399633].
35 Herrin J, da Graca B, Nicewander D, et al. The effectiveness of implementing an electronic health record on diabetes care and outcomes. Health Serv Res. Aug. 2012;47(4):1522-40. [pmid: 22250953].
36 Hunt JS, Siemienczuk J, Gillanders W, et al. The impact of a physician-directed health information technology system on diabetes outcomes in primary care: a pre- and post-implementation study. Inform Prim Care. 2009;17(3):165-74. [pmid: 20074429].
37 Litvin CB, Ornstein SM, Wessell AM, et al. Use of an electronic health record clinical decision support tool to improve antibiotic prescribing for acute respiratory infections: the ABX-TRIP study. J Gen Intern Med. Jun. 2013;28(6):810-6. [pmid: 23117955].
38 Kern LM, Barron Y, Dhopeshwarkar RV, et al. Electronic health records and ambulatory quality of care. J Gen Intern Med. Apr. 2013;28(4):496-503. [pmid: 23054927].
39 Kern LM, Barron Y, Dhopeshwarkar RV, et al. Health information exchange and ambulatory quality of care. Appl Clin Inform. 2012;3(2):197-209. [pmid: 23646072].
40 King J, Patel V, Jamoom EW, et al. Clinical benefits of electronic health record use: national findings. Health Serv Res. Feb. 2014;49(1 Pt 2):392-404. [pmid: 24359580].
41 Reed M, Huang J, Graetz I, et al. Outpatient electronic health records and the clinical care and outcomes of patients with diabetes mellitus. Ann Intern Med. Oct. 2. 2012;157(7):482-9. [pmid: 23027319].
42 Samal L, Linder JA, Lipsitz SR, et al. Electronic health records, clinical decision support, and blood pressure control. Am J Manag Care. Sep. 2011;17(9):626-32. [pmid: 21902448].
43 Garrido T, Jamieson L, Zhou Y, et al. Effect of electronic health records in ambulatory care: retrospective, serial, cross sectional study. Bmj. Mar. 12. 2005;330(7491):581. [pmid: 15760999].
44 Adler-Milstein J, Salzberg C, Franz C, et al. Effect of electronic health records on health care costs: longitudinal comparative evidence from community practices. Ann Intern Med. Jul. 16. 2013;159(2):97-104. [pmid: 23856682].
45 Spooner SA. We are still waiting for fully supportive electronic health records in pediatrics. Pediatrics. Dec. 2012;130(6):e1674-6. [pmid: 23166347].
46 Agency for Healthcare Research and Quality. Model Children's EHR Format. http://www.ahrq.gov/policymakers/chipra/ehrformatfaq.html. April 1, 2015.
47 HL7. HL7 EHR Child Health Functional Profile (CHFP), Release 1. http://www.hl7.org/implement/standards/product_brief.cfm?product_id=15. April 1, 2015.
48 Spooner SA. Special requirements of electronic health record systems in pediatrics. Pediatrics. Mar. 2007;119(3):631-7. [pmid: 17332220].
49 Nakamura MM, Harper MB, Jha AK. Change in adoption of electronic health records by US children's hospitals. Pediatrics. May. 2013;131(5):e1563-75. [pmid: 23589808].
50 Leu MG, O'Connor KG, Marshall R, et al. Pediatricians' use of health information technology: a national survey. Pediatrics. Dec. 2012;130(6):e1441-6. [pmid: 23166335].
51 Jha AK, DesRoches CM, Campbell EG, et al. Use of electronic health records in U.S. hospitals. N Engl J Med. Apr. 16. 2009;360(16):1628-38. [pmid: 19321858].
52 Centers for Disease Control and Prevention. Ambulatory Health Care Data. http://www.cdc.gov/nchs/ahcd.htm. April 1, 2015.
53 Lehmann CU, O'Connor KG, Shorte VA, et al. Use of electronic health record systems by office-based pediatricians. Pediatrics. Jan. 2015;135(1):e7-15. [pmid: 25548325].
54 Forrest CB, Simpson L, Clancy C. Child health services research Challenges and opportunities. Jama. Jun. 11. 1997;277(22):1787-93. [pmid: 9178792].
55 Au L, Oster A, Yeh GH, et al. Utilizing an electronic health record system to improve vaccination coverage in children. Appl Clin Inform. 2010;1(3):221-31. [pmid: 23616838].
56 Patterson ES, Zhang J, Abbott P, et al. Enhancing electronic health record usability in pediatric patient care: a scenario-based approach. Jt Comm J Qual Patient Saf. Mar. 2013;39(3):129-35. [pmid: 23516763].
57 Patwardhan A, Kelleher K, Cunningham D, et al. Improving the influenza vaccination rate in patients visiting pediatric rheumatology clinics using automatic best practice alert in electronic patient records. Pediatric Rheumatology. 13. Jul. 2012;10.
58 Nelson B. A138: clinical decision support to improve preventive care in pediatric systemic lupus erythematosus. Arthritis Rheumatol. Mar. Suppl 11. 2014;66:S181.
59 Zhu VJ, Grannis SJ, Tu W, et al. Evaluation of a clinical decision support algorithm for patient-specific childhood immunization. Artif Intell Med. Sep. 2012;56(1):51-7. [pmid: 22633492].
60 American Academy of Pediatrics: Task Force on Medical Informatics. Special requirements for electronic medical record systems in pediatrics. Pediatrics. Aug. 2001;108(2):513-5. [pmid: 11483828].
61 Carroll AE, Biondich PG, Anand V, et al. Targeted screening for pediatric conditions with the CHICA system. J Am Med Inform Assoc. Jul-Aug. 2011;18(4):485-90. [pmid: 21672910].
62 Bright Futures Guidelines for Health Supervision of Infants, Children, and Adolescents. 3rd edition. Elk Grove Village, IL. American Academy of Pediatrics. 2008. http://ebooks.aappublications.org/content/9781581102239/9781581102239. April 1, 2015.
63 Hagan JH Jr. Discerning bright futures of electronic health records. Pediatr Ann. Mar. 2008;37(3):173-9. [pmid: 18411861].
64 American Academy of Pediatrics, Partnership for Policy Implementation (PPI). Child Health Informatics Center. http://www2.aap.org/informatics/PPI.html. April 1, 2015.
65 Finnell SME, Stanton JL, Downs SM. Actionable Recommendations in the Bright Futures Child Health Supervision Guidelines. Appl Clin Inform. 2014;5(3):651-9. [pmid: 25298806].
66 Angier H, Gold R, Crawford C, et al. Linkage Methods for Connecting Children with Parents in Electronic Health Record and State Public Health Insurance Data. Matern Child Health J. 2014. Feb. 23. [pmid: 24562505].
67 ACOG Committee Opinion no. 599: Committee on Adoscent Health Care: Adolescent confidentiality and electronic health records. Obstet Gynecol. May. 2014;123(5):1148-50. [pmid: 24785881].
68 Blythe MJ, Del Beccaro MA. Standards for health information technology to ensure adolescent privacy. Pediatrics. Nov. 2012;130(5):987-90. [pmid: 23109684].
69 Swartz MK. Protecting the privacy rights of adolescents. J Pediatr Health Care. May-Jun. 2013;27(3):161. [pmid: 23611455].
70 Anoshiravani A, Gaskin GL, Groshek MR, et al. Special requirements for electronic medical records in adolescent medicine. J Adolesc Health. Nov. 2012;51(5):409-14. [pmid: 23084160].
71 Akinyele J, Lehmann CU, Green M, et al. Self-Protecting Electronic Medical Records Using Attribute-Based Encryption. Calhoun Institutional Archive of the Naval Postgraduate School. Monterey, CA. 2010. http://hdl.handle.net/10945/40165. April 1, 2015.
72 Hales J, Perkins M. Model Children's Electronic Health Record (EHR) Format: Environmental Scan and Gap Analysis. Rockville, MD. Westat. 2011.
73 Bourgeois FC, Taylor PL, Emans SJ, et al. Whose personal control? Creating private, personally controlled health records for pediatric and adolescent patients. J Am Med Inform Assoc. Nov-Dec. 2008;15(6):737-43. [pmid: 18755989].
74 Centers for Medicare and Medicaid Services. Electronic Health Record Incentive Program Stage 2. Final Rule. Fed Regist. Sept. 4. 2012;77(171):53968-4162.
75 Electronic Health Records Incentive Program. Medicare and Medicaid Programs, Federal Register. July. 28. 2010.
76 Bell LM, Grundmeier R, Localio R, et al. Electronic health record-based decision support to improve asthma care: a cluster-randomized trial. Pediatrics. Apr. 2010;125(4):e770-7. [pmid: 20231191].
77 Hughes RG, Edgerton EA. Reducing pediatric medication errors: children are especially at risk for medication errors. Am J Nurs. May. 2005;105(5):79-80. 2. 5 passim. [pmid: 15867545].
78 Lowry SZ, Quinn MT, Ramaiah M, et al. A human factors guide to enhance EHR usability of critical user interactions when supporting pediatric patient care NISTIR 7865. National Institute of Standards and Technology (US Department of Commerce). 2013. http://www.nist.gov/manuscript-publication-search.cfm?pub_id=911520. April 1, 2015.
79 Stavroudis TA, Miller MR, Lehmann CU. Medication errors in neonates. Clin Perinatol. Mar. 2008;35(1):141-61. ix. [pmid: 18280880].
80 Gerstle RS, Lehmann CU. Electronic prescribing systems in pediatrics: the rationale and functionality requirements. Pediatrics. Jun. 2007;119(6):e1413-22. [pmid: 17545368].
81 Johnson KB, Lee CK, Spooner SA, et al. Automated dose-rounding recommendations for pediatric medications. Pediatrics. Aug. 2011;128(2):e422-8. [pmid: 21788218].
82 Key Capabilities of an Electronic Health Record System: Letter Report. Washington, DC. The National Academies Press. 2003. http://www.nap.edu/catalog.php?record_id=10781. April 1, 2015.
83 Lehmann CU, Conner KG, Cox JM. Preventing provider errors: online total parenteral nutrition calculator. Pediatrics. Apr. 2004;113(4):748-53. [pmid: 15060223].
84 Zimmer K, Miller M, Lee B, et al. Electronic Narcotic Prescription Writer: Use in Medical Error Reduction. J Patient Saf. 2008;4(2):98-105.
85 Scharnweber C, Lau BD, Mollenkopf N, et al. Evaluation of medication dose alerts in pediatric inpatients. Int J Med Inform. Aug. 2013;82(8):676-83. [pmid: 23643148].
86 Clancy CM. Children's electronic health records: has the tipping point arrived?. J Comp Eff Res. Jul. 2013;2(4):359-61. [pmid: 24236674].
87 Ginzburg R, Barr WB, Harris M, et al. Effect of a weight-based prescribing method within an electronic health record on prescribing errors. Am J Health Syst Pharm. Nov. 15. 2009;66(22):2037-41. [pmid: 19890088].
88 Ordóñez P, desJardins M, Lombardi M, et al. An animated multivariate visualization for physiological and clinical data in the ICU. Proceedings of the 1st ACM International Health Informatics Symposium (IHI '10). Arlington, VA. Association for Computing Machinery (ACM). November 2010.
89 Rosenbloom ST, Qi X, Riddle WR, et al. Implementing pediatric growth charts into an electronic health record system. J Am Med Inform Assoc. May-Jun. 2006;13(3):302-8. [pmid: 16501182].
90 Rosenbloom ST, McGregor TL, Chen Q, et al. Specialized Pediatric Growth Charts For Electronic Health Record Systems: the example of Down syndrome. AMIA Annu Symp Proc. 2010;2010:687-91. [pmid: 21347066].
91 Rosenbloom ST, Butler MG. Development and implementation of electronic growth charts for infants with Prader-Willi syndrome. Am J Med Genet A. Nov. 2012;158a(11):2743-9. [pmid: 22903930].
92 Sankilampi U, Saari A, Laine T, et al. Use of electronic health records for automated screening of growth disorders in primary care. Jama. Sep. 11. 2013;310(10):1071-2. [pmid: 24026604].
93 McPheeters MM, Davis AM, Taylor JL, et al. Transition Care for Children With Special Health Needs. Technical Brief No. 15. Rockville, MD. Agency for Healthcare Research and Quality. June. 2014.
94 Lemly DC, Weitzman ER, O'Hare K. Advancing healthcare transitions in the medical home: tools for providers, families and adolescents with special healthcare needs. Curr Opin Pediatr. Aug. 2013;25(4):439-46. [pmid: 23770924].
95 Downs SM, van Dyck PC, Rinaldo P, et al. Improving newborn screening laboratory test ordering and result reporting using health information exchange. J Am Med Inform Assoc. Jan-Feb. 2010;17(1):13-8. [pmid: 20064796].
96 Klann JG, Anand V, Downs SM. Patient-tailored prioritization for a pediatric care decision support system through machine learning. J Am Med Inform Assoc. Dec. 2013;20(e2):e267-74. [pmid: 23886921].
97 ACOG Committee on Adolescent Health Care. ACOG Committee Opinion no. 599: Adolescent confidentiality and electronic health records. Obstet Gynecol. May. 2014;123(5):1148-50. [pmid: 24785881].
98 Recommended childhood and adolescent immunization schedule--United States, 2014. Pediatrics. Feb. 2014;133(2):357-63. [pmid: 24488304].
99 Health information technology and the medical home. Pediatrics. May. 2011;127(5):978-82. [pmid: 21518710].
100 Zipkin R, Schrager SM, Keefer M, et al. Improving home management plan of care compliance rates through an electronic asthma action plan. J Asthma. Aug. 2013;50(6):664-71. [pmid: 23574196].
101 Rapp KI, Jack L Jr, Post R, et al. The HEAL, Phase II Project: enhancing features of an electronic medical record system to improve adherence to asthma guidelines. J Health Care Poor Underserved. Feb. 2013;24(1 Suppl):20-8. [pmid: 23395941].
102 Pyles LA, Hines C, Patock M, et al. Development of a web-based database to manage American College of Emergency Physicians/American Academy of Pediatrics Emergency Information Forms. Acad Emerg Med. Mar. 2005;12(3):257-61. [pmid: 15741591].
103 Samaan ZM, Klein MD, Mansour ME, et al. The impact of the electronic health record on an academic pediatric primary care center. J Ambul Care Manage. Jul-Sep. 2009;32(3):180-7. [pmid: 19542807].
104 Flanagan JR, Walker KP. Tracking vaccine compliance in a primary care setting: online history, reminders, order entry, and charting. Proc AMIA Symp. 1999:760-4. [pmid: 10566462].
105 MacDonald SE, Schopflocher DP, Golonka RP. The pot calling the kettle black: the extent and type of errors in a computerized immunization registry and by parent report. BMC Pediatr. 2014;14:1. [pmid: 24387002].
106 Jensen RE, Chan KS, Weiner JP, et al. Implementing electronic health record-based quality measures for developmental screening. Pediatrics. Oct. 2009;124(4):e648-54. [pmid: 19786425].
107 Fairman AD, Thibadeau JK, Dicianno BE, et al. Implementing a specialty electronic medical record to document a life-course developmental model and facilitate clinical interventions in spina bifida clinics. Pediatr Clin North Am. Aug. 2010;57(4):959-71. [pmid: 20883885].
108 Bethell CD, Blumberg SJ, Stein RE, et al. Taking Stock of the CSHCN Screener: A Review of Common Questions and Current Reflections. Acad Pediatr. 2014. Dec. 5. [pmid: 25486969].
109 Desch L, Lipkin P. Children with Developmental Disorders and Other Special Needs. Lehmann C, Kim G, Johnson K, editors. Pediatric Informatics. Springer. New York. 2009:55-68.
110 Ferranti JM, Horvath MM, Jansen J, et al. Using a computerized provider order entry system to meet the unique prescribing needs of children: description of an advanced dosing model. BMC Med Inform Decis Mak. 2011;11:14. [pmid: 21338518].
111 Glynn C, Kleinman RE, Smith S, et al. The evolution and implementation of a pediatric computerized order entry system: a case study. J Healthc Inf Manag. Spring. 2004;18(2):64-9. [pmid: 15162721].
112 Hou JY, Cheng KJ, Bai KJ, et al. The effect of a Computerized pediatric dosing decision support system on pediatric dosing errors. Journal of Food and Drug Analysis. September. 2013;21(3):286-91.
113 Manias E, Kinney S, Cranswick N, et al. Interventions to Reduce Medication Errors in Pediatric Intensive Care. Ann Pharmacother. 2014. Jul. 24. [pmid: 25059205].
114 van Rosse F, Maat B, Rademaker CM, et al. The effect of computerized physician order entry on medication prescription errors and clinical outcome in pediatric and intensive care: a systematic review. Pediatrics. Apr. 2009;123(4):1184-90. [pmid: 19336379].
115 Conroy S, Sweis D, Planner C, et al. Interventions to reduce dosing errors in children: a systematic review of the literature. Drug Saf. 2007;30(12):1111-25. [pmid: 18035864].
116 Shekelle PG, Morton SC, Keeler EB. Costs and benefits of health information technology. Evid Rep Technol Assess (Full Rep). Apr. 2006;(132):1-71. [pmid: 17627328].
117 Ayash CR, Simon SR, Marshall R, et al. Evaluating the impact of point- of-care decision support tools in improving diagnosis of obese children in primary care. Obesity (Silver Spring). Mar. 2013;21(3):576-82. [pmid: 23592666].
118 Bissinger RL, Mueller M, Cox TH, et al. Antibiotic timing in neonates with suspected hospital-acquired infections. Adv Neonatal Care. Feb. 2013;13(1):22-8. quiz 9-30. [pmid: 23360855].
119 Bode DV, Roberts TA, Johnson C. Increased adolescent overweight and obesity documentation through a simple electronic medical record intervention. Mil Med. Jan. 2013;178(1):115-8. [pmid: 23356129].
120 Fiks AG, Grundmeier RW, Mayne S, et al. Effectiveness of decision support for families, clinicians, or both on HPV vaccine receipt. Pediatrics. Jun. 2013;131(6):1114-24. [pmid: 23650297].
121 Hacker K, Penfold R, Zhang F, et al. Impact of electronic health record transition on behavioral health screening in a large pediatric practice. Psychiatr Serv. Mar. 2012;63(3):256-61. [pmid: 22267253].
122 Kadmon G, Bron-Harlev E, Nahum E, et al. Computerized order entry with limited decision support to prevent prescription errors in a PICU. Pediatrics. Sep. 2009;124(3):935-40. [pmid: 19706588].
123 Kazemi A, Ellenius J, Pourasghar F, et al. The effect of Computerized Physician Order Entry and decision support system on medication errors in the neonatal ward: experiences from an Iranian teaching hospital. J Med Syst. Feb. 2011;35(1):25-37. [pmid: 20703588].
124 Keehbauch J, Miguel GS, Drapiza L, et al. Increased documentation and management of pediatric obesity following implementation of an EMR upgrade and education. Clin Pediatr (Phila). Jan. 2012;51(1):31-8. [pmid: 21885433].
125 Longhurst CA, Parast L, Sandborg CI, et al. Decrease in hospital-wide mortality rate after implementation of a commercially sold computerized physician order entry system. Pediatrics. Jul. 2010;126(1):14-21. [pmid: 20439590].
126 Maat B, Rademaker CM, Oostveen MI, et al. The effect of a computerized prescribing and calculating system on hypo- and hyperglycemias and on prescribing time efficiency in neonatal intensive care patients. JPEN J Parenter Enteral Nutr. Jan. 2013;37(1):85-91. [pmid: 22535919].
127 McCrory MC, Strouse JJ, Takemoto CM, et al. Computerized physician order entry improves compliance with a manual exchange transfusion protocol in the pediatric intensive care unit. J Pediatr Hematol Oncol. Mar. 2014;36(2):143-7. [pmid: 23619120].
128 Patwardhan A, Kelleher K, Cunningham D, et al. The use of a mandatory best practice reminder in the electronic record improves influenza vaccination rate in a pediatric rheumatology clinic. Clinical Governance. 2011;16(4):308-19.
129 Pollack AH, Kronman MP, Zhou C, et al. Automated Screening of Hospitalized Children for Influenza Vaccination. J Pediatric Infect Dis Soc. Mar. 2014;3(1):7-14. [pmid: 24567840].
130 Savinon C, Taylor JS, Canty-Mitchell J, et al. Childhood obesity: Can electronic medical records customized with clinical practice guidelines improve screening and diagnosis?. J Am Acad Nurse Pract. Aug. 2012;24(8):463-71. [pmid: 22845029].
131 Schriger DL, Baraff LJ, Buller K, et al. Implementation of clinical guidelines via a computer charting system: effect on the care of febrile children less than three years of age. J Am Med Inform Assoc. Mar-Apr. 2000;7(2):186-95. [pmid: 10730602].
132 Shaikh U, Berrong J, Nettiksimmons J, et al. Impact of Electronic Health Record Clinical Decision Support on the Management of Pediatric Obesity. Am J Med Qual. 2014. Jan. 13. [pmid: 24418755].
133 White P, Kenton K. Use of electronic medical record-based tools to improve compliance with cervical cancer screening guidelines: effect of an educational intervention on physicians' practice patterns. J Low Genit Tract Dis. Apr. 2013;17(2):175-81. [pmid: 23343700].
134 Yen K, Shane EL, Pawar SS, et al. Time motion study in a pediatric emergency department before and after computer physician order entry. Ann Emerg Med. Apr. 2009;53(4):462-8.e1. [pmid: 19026466].
135 Yu F, Salas M, Kim YI, et al. The relationship between computerized physician order entry and pediatric adverse drug events: a nested matched case-control study. Pharmacoepidemiol Drug Saf. Aug. 2009;18(8):751-5. [pmid: 19479715].
136 Stockwell MS, Catallozzi M, Camargo S, et al. Registry-Linked Electronic Influenza Vaccine Provider Reminders: A Cluster-Crossover Trial. Pediatrics. 2014. Dec. 29. [pmid: 25548331].
137 Smith AJ, Skow A, Bodurtha J, et al. Health information technology in screening and treatment of child obesity: a systematic review. Pediatrics. Mar. 2013;131(3):e894-902. [pmid: 23382447].
138 Miller PL, Frawley SJ, Sayward FG, et al. IMM/Serve: a rule-based program for childhood immunization. Proc AMIA Annu Fall Symp. 1996:184-8. [pmid: 8947653].
139 Miller PL, Frawley SJ, Sayward FG. Exploring three approaches for handling incomplete patient histories in a computer-based guideline for childhood immunization. Proc AMIA Symp. 1999:878-82. [pmid: 10566486].
140 Miller PL, Frawley SJ, Sayward FG. Maintaining and incrementally revalidating a computer-based clinical guideline: a case study. J Biomed Inform. Apr. 2001;34(2):99-111. [pmid: 11515416].
141 Johnson KB, Ho YX, Andrew Spooner S, et al. Assessing the reliability of an automated dose-rounding algorithm. J Biomed Inform. Oct. 2013;46(5):814-21. [pmid: 23792464].
142 Armijo D, McDonnell C, Werner K. Electronic Health Record Usability: Interface Design Considerations. AHRQ Publication No. 09 (10)-0091-2-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2009.
143 Centers for Medicare and Medicaid Services. Clinical Quality Measures: Pediatric Recommened Core Measures. 2014. http://www.cms.gov/Regulations-and-Guidance/Legislation/EHRIncentivePrograms/Recommended_Core_Set.html. April 1, 2015.