# Next Steps

Through discussion with our Key Informants and review of the literature, we have described functionalities that will support the pediatric clinician in caring for children. This technical brief is intended to provide an overview of current practice and research and to identify areas for improvement.

The brief was commissioned for use as part of a larger project being completed by CMS and AHRQ to prioritize functionalities for pediatric EHRs in order to promote their use and implementation. Clearly, this brief has also identified a number of areas that are in need of rigorous research and we hope that it will encourage researchers and funders to ensure that this empirical work is pursued. Given the small number of empirical studies providing an evidence base for what works in this field, it is clear that research that is more rigorous is needed to inform development and implementation. A number of studies have been identified as being in progress. Studies that are currently registered as ongoing are documented, including their populations, interventions, and outcomes under study in Appendix F. We identified 17 ongoing studies, most of which are being conducted at academic centers, on a range of clinical topics, including improving asthma care, increasing vaccination uptake, weight-based dosing and care for premature infants. We hope this report encourages all stakeholders to collaborate on this effort to improve electronic health records, ensuring we provide the best possible care for children.