# Methods

We used discussions with Key Informants, a search of the gray literature, and a search of the published literature to collect relevant data and descriptions.

## Data Collection

### Discussions With Key Informants

We engaged Key Informants to offer insight into pediatric-specific functionalities for electronic health records, and suggest issues of greatest importance to clinicians, patients, researchers, and payers. We searched the Web sites of relevant professional organizations and research and policy groups to identify stakeholders whose work or interests indicate a high likelihood of interest and expertise in the topic.

In consultation with the investigative team and the Agency for Healthcare Research and Quality (AHRQ), we assembled a list of individuals representing a clinical, policy, research, or vendor perspective. Seven of 10 invited individuals agreed to participate. Following approval by AHRQ of the completed Disclosure of Interest forms for proposed Key Informants, we conducted discussions with Key Informants, representing clinicians in practice as well as in policy roles in addition to accomplished researchers.

We conducted three group discussions by telephone with Key Informants. We invited the Key Informants to share their experiences and make suggestions to address the proposed Guiding Questions (GQs). Before the call, we provided the participants with a copy of the protocol and GQs. We recorded and transcribed the call discussion and generated a summary that we distributed to call participants.

We used the input from the Key Informants to establish functionalities considered to be of highest importance and weighed those against what we found most commonly in the literature. Ultimately, the data presented represent a Venn diagram of Key Informant input, functionalities identified in the literature and those described both by Key Informants and in the literature.

We conducted discussion calls with nine Key Informants. We were not required to obtain Office of Management and Budget (OMB) clearance for the Key Informant interviews because we included fewer than ten non-government associated participants. The Key Informants represented vendors, practicing pediatrician, quality improvement, public health, academic research.

More details on the Key Informants and the discussions are in Appendix B and Appendix C.

### Published Literature Search

We used a combination of controlled vocabulary terms and keywords to search the published literature for studies that specifically evaluated electronic health records in the pediatric health care setting. We used terms for electronic health records, computerized physician order entry (CPOE) and clinical decision support (CDS), as well as broad terms and descriptors for pediatrics. We searched the literature base from 1999 on. We reviewed the reference lists of retrieved publications for other potentially relevant publications missed by the search strategies. We present the literature search details in Appendix A. We screened the included literature for publications that addressed one or more GQs; we further evaluated the publications for evaluation studies that met prespecified criteria (Table 1) for GQ3 (Evidence Map).

Table 1 Inclusion and exclusion criteria for evaluation studies

Category | Criteria
Study population | Pediatric, outpatient
Publication languages | English only
Admissible evidence | [underlined: Study design] Randomized controlled trials, including wait-list control, cohorts with comparison, pre-post cohort without comparison, stepped wedge designs, and case-control. [underlined: Outcomes]; - Healthcare quality including safety and cost; - Improved workflow; - Job satisfaction for providers; - Patient outcomes including safety, quality, cost, equity, standardization, efficiency; - Patient and family involvement including education and shared decision making; [underlined: Other criteria] Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results.

To identify newly published relevant literature, we updated the literature search during peer review and the posting period for public comments. We incorporated the results from the literature update into the Technical Brief.

We developed forms (Appendix D) for screening and data collection from the published literature. We recorded the study design and study populations from relevant sources. We document reasons for exclusion of records that were promoted for full text review (Appendix G).

### Gray Literature Search

We augmented the searches we conducted in bibliographic databases by searching for gray literature. Examples of sources of gray literature include the Internet, government Web sites, clinical trial databases, trade publications, and meeting abstracts. We crosschecked the findings from the gray literature searches against the literature retrieval for publications that we may have missed in the literature searches.

We searched relevant professional association and organization Web sites, as well as State and Federal government Web sites descriptions or links to existing models. We present a summary of relevant consensus statements in Appendix E. We retrieved records from ClinicalTrials.gov to identify ongoing research (Appendix F).

To glean insight into the issues and concerns of users of pediatric EHRs, we collected the comments submitted by pediatric providers who reviewed their own EHR systems on the AAP Web site^c^ and summarized those by functionality (User Perspective from AAP Review System). The goal was to identify any themes that might emerge in users' spontaneous reviews of systems, but we should be clear that we did not conduct primary data collection to gather this information. It reflects those issues raised through the AAP.

c American Academy of Pediatrics (AAP), Council on Clinical Information Technology (COCIT). Electronic Medical Record (EMR) Review Project Web site. http://www.aapcocit.org/emr/readreviews.php.

## Data Organization and Presentation

We summarize information extracted from the published and gray literature in the results and discussion of this report. We identified themes from expert input and describe the findings from the literature, Key Informant discussions, and gray literature for each theme for GQ1. In GQ2, we address contextual issues including transition of care, health care setting, and implementation considerations from the literature base and the Key Informant input. For GQ3, we summarized existing systematic reviews and original research published since the end date of the systematic reviews. We present summary tables and text to characterize the existing evidence for pediatric-specific EHRs (GQ3). We highlight the roles of testability and usability in the successful dissemination and future development of pediatric-specific EHRs in GQ4.

Based initially on Key Informant input and with confirmation from the literature, we organize the report around eight categories for the pediatric functionalities: (1) vaccines; (2) routine health care maintenance; (3) family dynamics; (4) privacy; (5) managing pediatric populations; (6) medications; (7) documentation and billing; and (8) pediatric-specific norms and growth charts.

## Peer Review

A draft of this Technical Brief will be posted to the AHRQ Web site for 4 weeks for public comments. During this time, the Scientific Resource Center distributes the draft report to individuals who agreed to serve as peer reviewers. The Scientific Resource Center collects the feedback from peer reviewers and forwards the compiled comments to report authors. We will review the comments and made appropriate changes to the final report.

We will document the report revisions and provide a summary of responses to the individual comments received from public and peer reviewers in a disposition of comments table. The disposition of comments table will be available on the AHRQ Web site after publication of the final Technical Brief.