# Peer Reviewers

Prior to publication of the final evidence report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- William G. Adams, M.D.
  Boston University School of Medicine
  Boston, MA
- Martha Dewey Bergren, D.N.S., R.N., FAAN
  University of Illinois
  Chicago, IL
- Robert Grundmeier, M.D.
  Children's Hospital of Philadelphia
  Philadelphia, PA
- Chip Hart
  Physicians Computer Company
  Winooski, VT
- Rainu Kaushal, M.D., M.P.H.
  Weill Cornell Medical College
  New York, NY
- Alex R. Kemper, M.D., M.P.H.
  Duke University
  Durham, NC
- Michael G. Leu, M.D., M.S., M.H.S., FAAP
  Seattle Children's Hospital
  Seattle, WA
- Rita Mangione-Smith, M.D., M.P.H.
  University of Washington Department of Pediatrics
  Seattle Children's Research Institute
  Seattle, WA
- Eugenia Marcus, M.D.
  Wellesley Hills, MA
- Feliciano B. Yu, M.D., M.S.H.I., M.S.P.H., FAAP
  Washington University School of Medicine
  St. Louis Children's Hospital
  St. Louis, MO
- Alan E. Zuckerman, M.D.
  Georgetown University
  Washington DC