# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The Task Order Officer and the Evidence-based Practice Center work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Martha Dewey Bergren, D.N.S., R.N., FAAN
  University of Illinois
  Chicago, IL
- Barbara P. Byrne, M.D., M.B.A.
  Edward Health System
  Naperville, IL
- Mark A. Del Beccaro, M.D.
  University of Washington
  Seattle, WA
- Alexander G. Fiks, M.D., M.S.C.E.
  Children's Hospital of Philadelphia
  Philadelphia, PA
- Chip Hart
  Physicians Computer Company
  Winooski, VT
- Hetty G. Khan, B.S.N., M.S.N.I.
  Centers for Disease Control and Prevention
  Silver Spring, MD
- Susan J. Kressly, M.D., FAAP
  Kressly Pediatrics
  Warrington, PA
- Stephen Andrew Spooner, M.D., M.S., FAAP
  Cincinnati Children's Hospital
  Cincinnati, OH