# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Mr. Robert Goodrich and Ms. Tanya Surawicz screened literature and extracted data.