# Background

Clinicians, informaticians, policy makers, and professional organizations such as the American Academy of Pediatrics (AAP) have described the need for electronic health record (EHR) systems and information technology tools that better support pediatric health care through the availability of pediatric functionalities.1-3 In particular, they suggest that EHRs used in the care of children may increase patient safety through standardization of care and reducing errors and variability in documentation and communication of patient data.4-9 However, adoption has lagged, and lack of pediatric functionality is often cited as a reason for the lower rates of adoption in pediatrics.10,11 Furthermore, while EHRs may improve safety, implementation of generic EHR systems that do not meet pediatric functionality and work flow demands could be potentially dangerous.12-15

Empirical data describing the specific benefits of pediatric EHRs are scarce, and few studies have been conducted in the pediatric setting to assess the potential benefits of pediatric functionalities. Some studies describe improvements in immunization rates,8,16,17 attention-deficit/hyperactivity disorder care,18 preventive care counseling for children and adolescents,19,20and hepatitis C status followup in infants.21 Ultimately, available research on outcomes has yielded inconsistent results, potentially due to great variety and variability of systems reviewed.22-44

While the Health Information Technology for Economic and Clinical Health (HITECH) Act has promoted adoption of EHRs by providers and hospitals, development and implementation of functionality to promote quality of pediatric care specifically has been inconsistent, even among supporters of EHR implementation.45 Organizations including the Agency for Healthcare Research and Quality (AHRQ),46 Health Level 7 (HL7) International,47 and the AAP3 have attempted to achieve consistency by describing data formats and desired functionalities for use across pediatrics EHRs. Developed by AHRQ and CMS, the Children's EHR Format is particularly focused on the needs of children enrolled in Medicaid or the Children's Health Insurance Program.46

The question arises, however, in the face of several recommended core sets of functionalities for pediatric EHRs, which are truly essential. A 2007 AAP report noted immunization management, growth tracking, medication dosing, patient identification, data norms, terminology, and privacy as important concerns/requirements for EHR in pediatric populations.48 Recent recommendations from the Society for Adolescent Health and Medicine also urge that EHR designs take into account “the special needs of adolescents for access to health information and the vigorous protection of confidentiality” and note that EHR developers should ensure that systems meet regulatory requirements and privacy needs.22 These various recommendations may be based on a range of empirical or other evidence.

Despite lack of consistent recommendations, “Meaningful Use” incentives associated with the HITECH Act have resulted in increased implementation and use of EHRs by pediatricians.49 It is unclear whether providers are adopting pediatric-specific tools, however. For example, suggested minimum requirements for a “pediatric-supportive” EHR include well-child visit tracking, support for anthropometric analysis such as growth charts, immunization tracking and forecasting, and support for weight-based drug dosing.48,50 Only 31 percent of pediatricians use an EHR with basic functionality, and only 14 percent use a fully functional^a^ EHR.52 Only 8 percent of pediatricians are using a fully functional EHR with pediatric functionality.53

a During 2007-2009, NAMCS defined a fully functional EHR system as having all 14 functionalities in basic systems plus the following additional features: (1) medical history and followup notes; (2) drug interaction or contraindication warnings; (3) prescriptions sent to pharmacy electronically; (4) computerized orders for lab tests; (5) test orders sent electronically; (6) providing reminders for guideline-based interventions; (7) highlighting out-of-range lab values; (8) computerized orders for radiology tests.

American Hospital Association administered survey on EHR adoption defines comprehensive EHR to include the basic EHR core functionalities plus 14 additional functionalities implemented across all units (see Nakamura et al., 2013^49^ and Jha et al., 2009^51^).

The Children's EHR Format included almost 700 requirements pertaining to pediatric functionality.46 While the report included desired functions to support care of children, the large number of requirements may have had a paralyzing effect on vendors, who, additionally confronted with Meaningful Use requirements, did not leverage the format to improve their products. Reports from Children's Health Insurance Reauthorization Act D grantees indicate that vendors used a survey-based prioritization approach to identify items of high value to pediatrician and to add these items to their EHR design. Similarly, the HL7 requirements^b^ include over 100 unique pediatric items.

b HL7 EHR Child Health Functional Profile (CHFP), Release 1. Available at http://www.hl7.org/implement/standards/product_brief.cfm?product_id=15. .

## Scope

### Issues and Challenges in the Evidence Base

A significant challenge in this brief is the breadth of pediatric practice, including subgroups and special populations requiring specific elements of care that may merit specific EHR functionalities, all of which may diffuse agreement on key pediatric EHR features. Pediatric patients may range from a few hundred grams to hundreds of pounds in weight and their developmental status changes from completely dependent and helpless to independent, mature individuals. Fundamental to pediatric care is supporting the dynamic physiological and developmental changes to assure change is occurring at the right pace and time.54

Another challenge is that requirements and EHRs for inpatient and outpatient settings may differ based on the work performed and be represented differently in the literature. Similarly, individual reports may address specific elements of EHRs such as order entry or electronic prescribing. Stakeholder groups such as the AAP have published numerous position papers and recommendations, which will provide important themes and crosscutting approaches. As expected given the relatively recent increase in adoption of pediatric EHRs and the significant costs of implementing them, few controlled trials of their effects exist, and the field is developing rapidly. Data are not available uniformly across categories of care or functionalities. We will focus on the functionalities, needs, and desiderata uniquely relevant to pediatric care that extend beyond those functionalities available for adult care. Some functionality required for pediatric care is also critical for aspects of adult care, and we will include those critical features (e.g., immunization tracking, which is a key aspect of children's care as well as that of pregnant women).

## Technical Brief Objectives

A Technical Brief is a rapid report of an emerging intervention for which there are limited published data and too few completed research studies to support definitive conclusions. The goals of the Technical Brief are to provide an objective description of the state of the science, identify a potential framework for assessing the applications and implications of the intervention, summarize ongoing research, and present research gaps. A technical brief is not intended to be a comprehensive systematic review but should provide the reader with an overview of available research, practice and to some degree, perspective, around a given clinical intervention.

This report describes the state of the literature on pediatric EHR functionalities and their effects on outcomes of pediatric EHR implementation. We sought comparative studies that assessed the potential benefits of pediatric EHR use. We searched published reports and gray literature sources to ascertain the evidence for pediatric-specific EHR functionalities. In addition, we engaged stakeholders to augment the findings from the literature, and inform the summary of contextual issues, barriers, and potential challenges.

## Report Organization

We have organized the report by Guiding Question (GQ) and have summarized the available literature and Key Informant perspectives. GQ1, GQ2, and GQ4 reflect information found in published and unpublished literature, including opinion pieces and general materials. They also include the perspectives of our Key Informants. GQ3 is limited to a high-level evidence map of empirical studies. Thus, GQ1 and GQ2 lay out the issues that were found to be of highest relevance, while GQ3 identifies the available empirical literature on those issues. GQ4 then addresses challenges and opportunities related to implementation and dissemination.

### GQ1 Description of Pediatric-Specific Functionalities for EHRs

GQ1A: Are there functionalities that have been identified in the literature and feature more prominently than others as potentially important to achieve for improving children's health?

### GQ2 Description of the Context in Which EHRs Are Implemented

GQ2A: What is the potential value of pediatric-specific functionalities in the context of care transition, specifically from newborn care to pediatric primary care, from pediatric primary care to pediatric specialist care, and from pediatric primary care to adolescent care?

GQ2B: Are certain pediatric-specific functionalities beneficial for a provider to conduct her work including sick and well-child visits? If so, does this vary by health care setting (e.g. primary care office, specialty care office, school health, and alternative care settings) or by type of visit (e.g., preventive vs. acute care)?

GQ2C: What are the challenges to implementing specific functionalities? Are some harder than others to implement by (1) vendors; and/or (2) pediatric providers?

### GQ3 Description of the Existing Evidence

GQ3A: Is there any evidence that using an EHR adapted for the specific needs of pediatric providers compared with using a “regular” EHR or not using an EHR at all produces (1) better quality, including safety and cost outcomes for patients; and/or (2) improved workflow or job satisfaction for providers?

GQ3B: Which pediatric-specific functionalities influence (1) patient outcomes (including safety; quality; cost; equity; standardization of care; and/or efficiency); (2) the ability of a pediatric provider to conduct work within the EHR; (3) improvement of workflow and provider satisfaction; and/or (4) involvement of patients and families (including their education and shared decision making)?

### GQ4 Dissemination and Future Developments

GQ4A: How does testability and usability of core functionalities promote or impede dissemination and future development of pediatric EHRs?