# Reasons for Exclusion

Exclusion Code | Exclusion Reason | Count
X-1 | Not youth | 11
X-2 | Does not address pediatric-specific functionality or feature of an EHR | 147
X-3 | Not a health care setting | 40
X-4 | Not specific to outpatient | 53
X-5 | Does not address a guiding question | 53
X-6 | Unavailable/ non-English | 4
X-7 | Duplicate | 2

## References with reason(s) for exclusion

1 Electronic medical record could save millions. Hosp Case Manag. Dec. 1999;7(12):211-2. X-2. [pmid: 11184598].
2 Use guidelines to prepare for children with special needs, or risk tragedy. ED Manag. Aug. 2000;12(8):85-90. suppl 1-2. X-5. [pmid: 11186740].
3 Immunization information system progress--United States, 2003. MMWR Morb Mortal Wkly Rep. Jul. 29. 2005;54(29):722-4. X-5. [pmid: 16049421].
4 Study: implementation of CPOE can raise mortality. Healthcare Benchmarks Qual Improv. Feb. 2006;13(2):16-7. X-2, X-4. [pmid: 16544556].
5 Guideline on record-keeping. Pediatr Dent. 2008;30(7 Suppl):226-33. X-2. [pmid: 19216426].
6 Report urges development in Children's Health IT. Biomed Instrum Technol. Sep-Oct. 2009;43(5):350. X-2. [pmid: 19842752].
7 Computerized decision support for pediatric meds--effectiveness uncertain. Health Devices. Dec. 2012;41(12):400-1. X-2. [pmid: 23444688].
8 Abramson EL, Kaushal R. Computerized provider order entry and patient safety. Pediatr Clin North Am. Dec. 2012;59(6):1247-55. X-2. [pmid: 23116522].
9 Adhikari PD, Parker LA, Binns HJ, et al. Influence of electronic health records and in-office weight management support resources on childhood obesity care. Clin Pediatr (Phila). Aug. 2012;51(8):788-92. X-2. [pmid: 21576184].
10 Aguila A, Valenzuela P. Experience with electronic files in a university neonatology unit. Rev Med Chil. Feb. 2005;133(2):241-5. X-5. [pmid: 15824836].
11 Alvarado MM, Ntaimo L, Banerjee A, et al. Reducing pediatric medication errors: A survey and taxonomy. IIE Transactions on Healthcare Systems Engineering. April. 2012;2(2):142-55. X-2, X-5.
12 Amirthalingam G, White J, Ramsay M. Measuring childhood vaccine coverage in England: the role of Child Health Information Systems. Euro Surveill. 2012;17(16). X-3. [pmid: 22551461].
13 Anderson HJ. Avoiding ‘alert fatigue’. Health Data Manag. Oct. 2009;17(10):42. X-2. [pmid: 19845096].
14 Andrews AL, Kazley AS, Basco WT Jr., et al. Lower Rates of EMR Use in Rural Hospitals Represent a Previously Unexplored Child Health Disparity. Hosp Pediatr. Jul. 2014;4(4):211-6. X-5. [pmid: 24986989].
15 Auber BA, Hamel G. Adoption of smart cards in the medical sector: the Canadian experience. Soc Sci Med. Oct. 2001;53(7):879-94. X-1. [pmid: 11522135].
16 Bellazzi R, Riva A, Montani S, et al. Application report: preliminary evaluation of the T-IDDM project in Pavia. Stud Health Technol Inform. 1999;68:99-101. X-2. [pmid: 10725043].
17 Ben Said M, Robel L, Vion E, et al. Implementation and experimentation of TEDIS: an information system dedicated to patients with pervasive developmental disorders. Stud Health Technol Inform. 2011;169:270-4. X-4. [pmid: 21893755].
18 Ben Said M, Robel L, Vion E, et al. TEDIS: an information system dedicated to patients with pervasive developmental disorders. Stud Health Technol Inform. 2010;160(Pt 1):198-202. X-5. [pmid: 20841677].
19 Bennett WE Jr., Hendrix KS, Thompson RT, et al. The natural history of weight percentile changes in the first year of life. JAMA Pediatr. Jul. 2014;168(7):681-2. X-2. [pmid: 24797161].
20 Berry MD. Healthcare reform: administrative rulemaking. Issue brief. Issue Brief Health Policy Track Serv. Dec. 2012;31:1-29. X-2. [pmid: 23297441].
21 Blond MH, Menguy C, Gold F, et al. Medical informatics (hospital information systems) in neonatology: reality and insufficiencies. Arch Pediatr. Nov. 2000;7(11):1212-9. X-3, X-4. [pmid: 11109950].
22 Bourgeois FC, Linder J, Johnson SA, et al. Impact of a computerized template on antibiotic prescribing for acute respiratory infections in children and adolescents. Clin Pediatr (Phila). Oct. 2010;49(10):976-83. X-2. [pmid: 20724348].
23 Brady TM, Neu AM, Miller ER 3rd, et al. Real-Time Electronic Medical Record Alerts Increase High Blood Pressure Recognition in Children. Clin Pediatr (Phila). 2014. Nov. 20. X-2. [pmid: 25416626].
24 Burridge AM, Wilson K, Terry D. Support tools for paediatric inpatient prescribers: A review. European Journal of Hospital Pharmacy: Science and Practice. April. 2014;21(2):113-7. X-4.
25 Caldwell NA, Power B. The pros and cons of electronic prescribing for children. Arch Dis Child. Feb. 2012;97(2):124-8. X-2. [pmid: 21685504].
26 Call RJ, Burlison JD, Robertson JJ, et al. Adverse Drug Event Detection in Pediatric Oncology and Hematology Patients: Using Medication Triggers to Identify Patient Harm in a Specialized Pediatric Patient Population. J Pediatr. 2014. Apr. 24. X-4. [pmid: 24768254].
27 Canon SJ, Purifoy JA, Heulitt GM, et al. Results: Survey of pediatric urology electronic medical records-use and perspectives. J Urol. Oct. 2011;186(4 Suppl):1740-4. X-3. [pmid: 21862073].
28 Castellanos I, Rellensmann G, Scharf J, et al. Computerized Physician Order Entry (CPOE) in pediatric and neonatal intensive care: Recommendations how to meet clinical requirements. Appl Clin Inform. 2012;3(1):64-79. X-5. [pmid: 23616901].
29 Cerda G, Zatzick D, Wise M, et al. Computerized registry recording of psychiatric disorders of pediatric patients with burns. J Burn Care Rehabil. Jul-Aug. 2000;21(4):368-70. discussion 7. X-2, X-4. [pmid: 10935820].
30 Chen AR, Lehmann CU. Computerized provider order entry in pediatric oncology: design, implementation, and outcomes. J Oncol Pract. Jul. 2011;7(4):218-22. X-2. [pmid: 22043183].
31 Chern JJ, Macias CG, Jea A, et al. Effectiveness of a clinical pathway for patients with cerebrospinal fluid shunt malfunction. J Neurosurg Pediatr. Oct. 2010;6(4):318-24. X-3. [pmid: 20887102].
32 Chin TL. Assembling the records puzzle. Health Data Manag. Jan. 8. 1999;7(1):36-40. X-2. [pmid: 10345794].
33 Chiu SH, Fitzgerald KM. Electronic medical/health record and pediatric behavioral health providers: progress and problems. Arch Psychiatr Nurs. Apr. 2013;27(2):108-9. X-2. [pmid: 23540522].
34 Christensen M. The use of electronic medical records can contribute in diagnosing a case of battered child. Ugeskr Laeger. Jan. 28. 2013;175(5):284-5. X-2. [pmid: 23369331].
35 Coffey C, Wurster LA, Groner J, et al. A Comparison of Paper Documentation to Electronic Documentation for Trauma Resuscitations at a Level I Pediatric Trauma Center. J Emerg Nurs. 2014. Jul. 1. X-4. [pmid: 24996509].
36 Coleman NE, Pon S. Quality: performance improvement, teamwork, information technology and protocols. Crit Care Clin. Apr. 2013;29(2):129-51. X-3, X-4. [pmid: 23537668].
37 Condren M, Studebaker IJ, John BM. Prescribing errors in a pediatric clinic. Clin Pediatr (Phila). Jan. 2010;49(1):49-53. X-2. [pmid: 19643978].
38 Cook JE. The HITECH Act and electronic health records' limitation in coordinating care for children with complex chronic conditions. J Allied Health. Summer. 2014;43(2):117-20. X-5 X-. [pmid: 24925039].
39 Costa FF, Foly LS, Coutinho MP. DataGenno: building a new tool to bridge molecular and clinical genetics. Appl Clin Genet. 2011;4:45-54. X-2. [pmid: 23776366].
40 Costakos DT. Of lobsters, electronic medical records, and neonatal total parenteral nutrition. Pediatrics. Feb. 2006;117(2):e328-32. X-4. [pmid: 16452339].
41 Cramer JG. ‘We bought the wrong EMR’. Med Econ. Feb. 5. 2010;87(3):28-30. X-2. [pmid: 20337171].
42 Crossno CL, Cartwright JA, Hargrove FR. Using CPOE to improve communication, safety, and policy compliance when ordering pediatric chemotherapy. Hospital Pharmacy. April. 2007;42(4):368-73. X-4.
43 Dattani N, Hardelid P, Davey J, et al. Accessing electronic administrative health data for research takes time. Arch Dis Child. May. 2013;98(5):391-2. X-2. [pmid: 23448863].
44 de Jose MI, Jimenez de Ory S, Espiau M, et al. A new tool for the paediatric HIV research: general data from the Cohort of the Spanish Paediatric HIV Network (CoRISpe). BMC Infect Dis. 2013;13:2. X-2. [pmid: 23282073].
45 Despotova-Toleva LD. A model of a computer file for the intensive neonatal practice “Neonatal Intensive Computer File”. Folia Med (Plovdiv). 1999;41(2):38-43. X-4. [pmid: 10534912].
46 Dickens DS, Sinsabaugh D. Impact of computerized prescriber order entry on the incidence of adverse drug events in pediatric inpatients. Pediatrics. Sep. 2008;122(3):678. author reply -9. X-3, X-4. [pmid: 18762542].
47 Disabato JA, Levisohn P, Hutton L, et al. Improving transition to adult epilepsy care: Facilitating team communication using clinical decision support in the EMR. Epilepsy Currents. January-February. 2014;14:151. X-2.
48 Downing GJ, Zuckerman AE, Coon C, et al. Enhancing the quality and efficiency of newborn screening programs through the use of health information technology. Semin Perinatol. Apr. 2010;34(2):156-62. X-5. [pmid: 20207265].
49 Dryden EM, Hardin J, McDonald J, et al. Provider perspectives on electronic decision supports for obesity prevention. Clin Pediatr (Phila). May. 2012;51(5):490-7. X-2. [pmid: 22330047].
50 Duffy FH. Long latency evoked potential database for clinical applications: justification and examples. Clin EEG Neurosci. Apr. 2005;36(2):88-98. X-2, X-3. [pmid: 15999904].
51 Durand S, Rideau Batista Novais A, Mesnage R, et al. Validation of nosocomial infection in neonatology: A new method for standardized surveillance. Am J Infect Control. Aug. 2014;42(8):861-4. X-3, X-4. [pmid: 24930956].
52 Ellis-Davies K, Sakkalou E, Fowler NC, et al. CUE: the continuous unified electronic diary method. Behav Res Methods. Dec. 2012;44(4):1063-78. X-2, X-3. [pmid: 22648694].
53 Ellsworth MA, Carey WA, Li M, et al. Implementation of an electronic data monitoring system decreases the rate of hyperoxic episodes in premature neonates. J Perinatol. Sep. 2013;33(9):721-4. X-5. [pmid: 23579491].
54 Ewalt DH. Editorial comment. J Urol. Oct. 2011;186(4 Suppl):1745. discussion. X-2, X-5. [pmid: 21862077].
55 Ferranti JM, Horvath MM, Jansen J, et al. Using a computerized provider order entry system to meet the unique prescribing needs of children: description of an advanced dosing model. BMC Med Inform Decis Mak. 2011;11:14. X-5 X-4. [pmid: 21338518].
56 Figge HL. E-prescribing and the impact on medication dispensing errors. U.S. Pharmacist. July. 2012;37(7):31-3. X-2.
57 Fiks AG, Grundmeier RW, Margolis B, et al. Comparative effectiveness research using the electronic medical record: an emerging area of investigation in pediatric primary care. J Pediatr. May. 2012;160(5):719-24. X-2. [pmid: 22364853].
58 Fiks AG, Zhang P, Localio AR, et al. Adoption of Electronic Medical Record-Based Decision Support for Otitis Media in Children. Health Serv Res. 2014. Oct. 6. X-2. [pmid: 25287670].
59 Fine AM, Kalish LA, Forbes P, et al. Parent-driven technology for decision support in pediatric emergency care. Jt Comm J Qual Patient Saf. Jun. 2009;35(6):307-15. X-3, X-4. [pmid: 19565690].
60 Finkel E. Caring for kids, with technology by their side. Children's Medical's Durovich sees IT as tool to ‘help us do what we do better’. Mod Healthc. Jun. 13. 2011;41(24):25-6. X-2. [pmid: 21714400].
61 Finnell SM, Stanton JL, Downs SM. Actionable recommendations in the Bright Futures child health supervision guidelines. Appl Clin Inform. 2014;5(3):651-9. X-7. [pmid: 25298806].
62 Ford-Jones A. Practice Tips. Immunization tracker for primary care physicians. Can Fam Physician. Dec. 1999;45:2875-6. X-2. [pmid: 10626053].
63 Forrest CB, Fiks AG, Bailey LC, et al. Improving adherence to otitis media guidelines with clinical decision support and physician feedback. Pediatrics. Apr. 2013;131(4):e1071-81. X-2. [pmid: 23478860].
64 Frankovich J, Longhurst CA, Sutherland SM. Evidence-based medicine in the EMR era. N Engl J Med. Nov. 10. 2011;365(19):1758-9. X-2, X-5. [pmid: 22047518].
65 Frenn KA, Hendrickson M, Kharbanda AB. Reducing pediatric CT usage through web-based education. Radiol Manage. May-Jun. 2014;36(3):12-6. quiz 7-8. X-2. [pmid: 25004681].
66 Frize M, Catley C, Walker CR, et al. Towards a web services infrastructure for perinatal, obstetrical, and neonatal clinical decision support. Conf Proc IEEE Eng Med Biol Soc. 2004;5:3334-7. X-2, X-3, X-4. [pmid: 17270996].
67 Giannone G. Computer-supported weight-based drug infusion concentrations in the neonatal intensive care unit. Comput Inform Nurs. Mar-Apr. 2005;23(2):100-5. X-4. [pmid: 15772511].
68 Ginsberg HG. Since Katrina: neonatal and pediatric issues from both sides of the levee. Pediatrics. Aug. 2011;128(Suppl 1):S15-7. X-2. [pmid: 21807705].
69 Ginsburg G. Medical genomics: Gather and use genetic data in health care. Nature. Apr. 24. 2014;508(7497):451-3. X-2. [pmid: 24765668].
70 Glasper EA, Holmes CW, Brown KL, et al. Shared records: towards collaborative working with families. Paediatr Nurs. Feb. 2006;18(1):34-7. X-5 X-. [pmid: 16518952].
71 Goedert J. A real shot in the arm. Health Data Manag. Feb. 2000;8(2):34. 6. 8. X-2. [pmid: 11183663].
72 Gold J, Reyes-Gastelum D, Turner J, et al. A quality improvement study using fishbone analysis and an electronic medical records intervention to improve care for children with asthma. Am J Med Qual. Jan-Feb. 2014;29(1):70-7. X-2. [pmid: 23574643].
73 Gonzalez-Heydrich J, DeMaso DR, Irwin C, et al. Implementation of an electronic medical record system in a pediatric psychopharmacology program. Int J Med Inform. Jul. 2000;57(2-3):109-16. X-3, X-4. [pmid: 10961567].
74 Grech V. The impact of information technology on pediatric cardiology: present, past, and future. Pediatr Cardiol. Jul-Aug. 2000;21(4):324-7. X-2, X-3. [pmid: 10865006].
75 Greenwood JL, Narus SP, Leiser J, et al. Measuring body mass index according to protocol: how are height and weight obtained?. J Healthc Qual. May-Jun. 2011;33(3):28-36. X-1, X-2. [pmid: 22414017].
76 Grigull L, Betzel C, Schumacher U, et al. Should paediatricians use a computer to receive diagnostic support?. [German]. Padiatrische Praxis. December. 2012;79(4):545-55. X-2, X-6.
77 Grigull L, Lechner WM. Supporting diagnostic decisions using hybrid and complementary data mining applications: a pilot study in the pediatric emergency department. Pediatr Res. Jun. 2012;71(6):725-31. X-5. [pmid: 22441377].
78 Grisso AG, Wright L, Hargrove FR. The Pharmacist's Role in CPOE: A Pediatric Perspective. Hospital Pharmacy. November. 2003;38(11):1086-9+104. X-6.
79 Guilday P. The student health collaboration: an innovative approach to enhancing communication and improving student health. NASN Sch Nurse. Sep. 2014;29(5):244-7. X-3, X-4. [pmid: 25272411].
80 Hadley AM. Progress towards the clinical workstation at the New Children's Hospital. Health Inf Manag. Mar-May. 1999;29(1):42-3. X-2. [pmid: 10977172].
81 Hagland M. CPOE and patient safety. Healthc Inform. Jun. 2011;28(6):76-8. X-2. [pmid: 21736218].
82 Hanauer DA, Zheng K. Detecting workflow changes after a CPOE implementation: a sequential pattern analysis approach. AMIA Annu Symp Proc. 2008:963. X-4. [pmid: 18999105].
83 Hazelzet JA. Computerized physician order entry: friend or foe?. Pediatr Crit Care Med. May. 2007;8(3):304-5. X-2. [pmid: 17496521].
84 Hedden EM, Jessop AB, Field RI. Childhood immunization information system exchange with payers: State and federal policies. Journal of Managed Care Medicine. 2012;15(3):11-8. X-2, X-5.
85 Hicken VN, Thornton SN, Rocha RA. Integration challenges of clinical information systems developed without a shared data dictionary. Stud Health Technol Inform. 2004;107(Pt 2):1053-7. X-5. [pmid: 15360973].
86 Hing E, Hsiao CJ. State variability in supply of office-based primary care providers: United States, 2012. NCHS Data Brief. May. 2014;(151):1-8. X-2. [pmid: 24813076].
87 Hinman AR, Eichwald J, Linzer D, et al. Integrating child health information systems. Am J Public Health. Nov. 2005;95(11):1923-7. X-2. [pmid: 16195524].
88 Hinman AR, Saarlas KN, Ross DA. A vision for child health information systems: developing child health information systems to meet medical care and public health needs. J Public Health Manag Pract. Nov. 2004;(Suppl):S91-8. X-5 X-. [pmid: 15643366].
89 Holmes M. Andrew Szende and the development of the electronic Child Health Network (eCHN). Healthc Q. 2010;13(3):26-9. X-2, X-5. [pmid: 20523148].
90 Hoyle T, Swanson R. Assessing what child health information systems should be integrated: the Michigan experience. J Public Health Manag Pract. Nov. 2004;(Suppl):S66-71. X-2. [pmid: 15643362].
91 Huff C. Hospital to test if EMR, other innovations boost care for Medicaid kids. Cook Children's opens a new clinic to ‘learn what works and what doesn't’. Hosp Health Netw. Oct. 2009;83(10):17. X-2. [pmid: 19967812].
92 Issenman RM, Jaffer IH. Use of voice recognition software in an outpatient pediatric specialty practice. Pediatrics. Sep. 2004;114(3):e290-3. X-2. [pmid: 15342888].
93 Jackson G. Child abuse: a computerised register 40 years after it was proposed. Int J Clin Pract. Mar. 2013;67(3):191-2. X-2. [pmid: 23409684].
94 Jacobs B. Hardly child's play: implementing a pediatric-specific, integrated CPOE system. Midwest pediatric hospital tackles all the hurdles--needs assessment, clinician buy-in, training and measuring results--as it strengthens its patient safety efforts with wireless CPOE. Health Manag Technol. Aug. 2004;25(8):30-2. X-5. [pmid: 15328958].
95 Jacobs BR, Hart KW, Rucker DW. Reduction in Clinical Variance Using Targeted Design Changes in Computerized Provider Order Entry (CPOE) Order Sets: Impact on Hospitalized Children with Acute Asthma Exacerbation. Appl Clin Inform. 2012;3(1):52-63. X-5. [pmid: 23616900].
96 Jacobs JP, Maruszewski B, Tchervenkov CI, et al. The current status and future directions of efforts to create a global database for the outcomes of therapy for congenital heart disease. Cardiol Young. Feb. Suppl 1. 2005;15:190-7. X-2, X-4. [pmid: 15934716].
97 Jaspers MW, Steen T, van den Bos C, et al. The think aloud method: a guide to user interface design. Int J Med Inform. Nov. 2004;73(11-12):781-95. X-2, X-5. [pmid: 15491929].
98 Jenders RA, Dasgupta B, Mercedes D, et al. Use of a hospital practice management system to provide initial data for a pediatric immunization registry. Proc AMIA Symp. 1999:286-90. X-5. [pmid: 10566366].
99 Johnson KE, Beaton SJ, Andrade SE, et al. Methods of linking mothers and infants using health plan data for studies of pregnancy outcomes. Pharmacoepidemiol Drug Saf. Jul. 2013;22(7):776-82. X-5. [pmid: 23596095].
100 Johnson KH, Guthrie S. Harnessing the power of student health data: Selecting, using, and implementing electronic school health documentation systems. NASN Sch Nurse. Jan. 2012;27(1):26-33. X-2, X-3. [pmid: 22720477].
101 Jones JL. Implementing computerized prescriber order entry in a children's hospital. Am J Health Syst Pharm. Nov. 15. 2004;61(22):2425-9. X-2. [pmid: 15581267].
102 Kalra D, Fernando B. Approaches to enhancing the validity of coded data in electronic medical records. Prim Care Respir J. Mar. 2011;20(1):4-5. X-2. [pmid: 21060979].
103 Kaushal R, Barker KN, Bates DW. How can information technology improve patient safety and reduce medication errors in children's health care?. Arch Pediatr Adolesc Med. Sep. 2001;155(9):1002-7. X-2. [pmid: 11529801].
104 Kelleher KJ, Horwitz SM. Quality of mental health care for children: a familiar storyline. Med Care. Dec. 2006;44(12):1061-3. X-2. [pmid: 17122708].
105 Kelly B. A records system for kids. Health Data Manag. May. 2002;10(5):30-2. 4. X-2. [pmid: 12017101].
106 Kemper AR, Uren RL, Clark SJ. Adoption of electronic health records in primary care pediatric practices. Pediatrics. Jul. 2006;118(1):e20-4. X-5 X-. [pmid: 16818534].
107 Kern LM, Barron Y, Dhopeshwarkar RV, et al. Electronic health records and ambulatory quality of care. J Gen Intern Med. Apr. 2013;28(4):496-503. X-2. [pmid: 23054927].
108 Kim GR, Lehmann CU. Pediatric aspects of inpatient health information technology systems. Pediatrics. Dec. 2008;122(6):e1287-96. X-3, X-4. [pmid: 19047228].
109 Kim GR, Miller MR, Ardolino MA, et al. Capture and classification of problems during CPOE deployment in an academic pediatric center. AMIA Annu Symp Proc. 2007:414-7. X-2. [pmid: 18693869].
110 Klass P. Disconnected. N Engl J Med. Apr. 15. 2010;362(15):1358-61. X-2. [pmid: 20393174].
111 Knaup P, Wiedemann T, Wolff A, et al. Computer-assisted documentation and therapy planning in pediatric oncology--introduction of a nationwide solution. Klin Padiatr. Jul-Aug. 1999;211(4):189-91. X-3. [pmid: 10472547].
112 Kramer T, Iliffe S, Bye A, et al. Testing the feasibility of therapeutic identification of depression in young people in British general practice. J Adolesc Health. May. 2013;52(5):539-45. X-2, X-3. [pmid: 23608718].
113 Lazou K, Farini M, Koutkias V, et al. Adverse drug event prevention in neonatal care: a rule-based approach. Stud Health Technol Inform. 2013;186:170-4. X-3. [pmid: 23542991].
114 Lee EK, Mejia AF, Senior T, et al. Improving Patient Safety through Medical Alert Management: An Automated Decision Tool to Reduce Alert Fatigue. AMIA Annu Symp Proc. 2010;2010:417-21. X-2. [pmid: 21347012].
115 Lemon V, Stockwell DC. Automated detection of adverse events in children. Pediatr Clin North Am. Dec. 2012;59(6):1269-78. X-2. [pmid: 23116524].
116 Lenclen R. Computerized physician order entry softwares for pediatric units. Arch Pediatr. Jun. 2005;12(6):918-20. X-4. [pmid: 15904850].
117 Leu MG, O'Connor KG, Marshall R, et al. Pediatricians' use of health information technology: a national survey. Pediatrics. Dec. 2012;130(6):e1441-6. X-2. [pmid: 23166335].
118 Levenson D. NIH to include children's genomic data in electronic medical records. Am J Med Genet A. Nov. 2011;155a(11):ix-x. X-3, X-4. [pmid: 22021228].
119 Li Q, Melton K, Lingren T, et al. Phenotyping for patient safety: algorithm development for electronic health record based automated adverse event and medical error detection in neonatal intensive care. J Am Med Inform Assoc. 2014. Jan. 8. X-3, X-4. [pmid: 24401171].
120 Lillis K. Automated dosing. Computerized physician order entry reduces risk of medication and dosing errors in neonatal ICU. Health Manag Technol. Nov. 2003;24(11):36-7. X-4. [pmid: 14608711].
121 Lin M, Brooks TN, Miller AC, et al. English-based pediatric emergency medicine software improves physician test performance on common pediatric emergencies: A multicenter study in Vietnam. Western Journal of Emergency Medicine. 2013;14(5):471-6. X-2. [pmid: 24106545].
122 Lipton J, Hazelzet JA. Clinical decision support systems: Important tools when appropriately used. Pediatr Crit Care Med. Jan. 2009;10(1):128-9. X-4. [pmid: 19131870].
123 List BA, Ballard JL, Langworthy KS, et al. Electronic health records in an outpatient breastfeeding medicine clinic. J Hum Lact. Feb. 2008;24(1):58-68. X-2. [pmid: 18281357].
124 Litvin CB, Ornstein SM, Wessell AM, et al. Use of an electronic health record clinical decision support tool to improve antibiotic prescribing for acute respiratory infections: the ABX-TRIP study. J Gen Intern Med. Jun. 2013;28(6):810-6. X-1. [pmid: 23117955].
125 Livon D, Abaziou JM, Franceschini JC, et al. The electronic health record of the child, a natural evolution. [French]. Journal de Pediatrie et de Puericulture. August. 2005;18(5):224-7. X-2, X-5.
126 Livon D, Abaziou JM, Franceschini JC, et al. Electronic health record of children, a natural evolution. [French]. Actualites Pharmaceutiques. January. 2006;(448):10-1. X-6.
127 Locke R, Stefano M, Koster A, et al. Optimizing patient/caregiver satisfaction through quality of communication in the pediatric emergency department. Pediatr Emerg Care. Nov. 2011;27(11):1016-21. X-3, X-4. [pmid: 22068060].
128 Lomotan EA, Hoeksema LJ, Edmonds DE, et al. Evaluating the use of a computerized clinical decision support system for asthma by pediatric pulmonologists. Int J Med Inform. Mar. 2012;81(3):157-65. X-3. [pmid: 22204897].
129 Longhurst C, Sharek P, Hahn J, et al. Perceived increase in mortality after process and policy changes implemented with computerized physician order entry. Pediatrics. Apr. 2006;117(4):1450-1. author reply 5-6. X-4. [pmid: 16585351].
130 Longhurst C, Turner S, Burgos AE. Development of a Web-based decision support tool to increase use of neonatal hyperbilirubinemia guidelines. Jt Comm J Qual Patient Saf. May. 2009;35(5):256-62. X-3. [pmid: 19480378].
131 Lu M, Ownby DR, Zoratti E, et al. Improving efficiency and reducing costs: Design of an adaptive, seamless, and enriched pragmatic efficacy trial of an online asthma management program. Contemp Clin Trials. May. 2014;38(1):19-27. X-5 X-. [pmid: 24607295].
132 Lykowski G, Mahoney D. Computerized provider order entry improves workflow and outcomes. Nurs Manage. Feb. 2004;35(2):40g-h. X-4. [pmid: 14767222].
133 Matheson A, Diaz A. Getting the record straight: the story of one NACCHO demonstration site's efforts to improve child health. J Public Health Manag Pract. Nov-Dec. 2009;15(6):535-7. X-2. [pmid: 19823160].
134 Maughan ED, Johnson KH, Bergren MD, et al. Standardized data set for school health services: Part 1--getting to big data. NASN Sch Nurse. Jul. 2014;29(4):182-6. X-3, X-4. [pmid: 25141454].
135 Mayne SL, duRivage NE, Feemster KA, et al. Effect of decision support on missed opportunities for human papillomavirus vaccination. Am J Prev Med. Dec. 2014;47(6):734-44. X-2. [pmid: 25455116].
136 Mazars N, Milesi C, Carbajal R, et al. Implementation of a neonatal pain management module in the computerized physician order entry system. Ann Intensive Care. 2012;2(1):38. X-5. [pmid: 22913821].
137 McCartney PR. Using technology to promote perinatal patient safety. J Obstet Gynecol Neonatal Nurs. May-Jun. 2006;35(3):424-31. X-4. [pmid: 16700694].
138 McKenna C, Gaines B, Hatfield C, et al. Implementation of a screening, brief intervention, and referral to treatment program using the electronic medical record in a pediatric trauma center. J Trauma Nurs. Jan-Mar. 2013;20(1):16-23. X-3, X-4. [pmid: 23459427].
139 Menachemi N, Brooks RG, Schwalenstocker E, et al. Use of health information technology by children's hospitals in the United States. Pediatrics. Jan. 2009;123(Suppl 2):S80-4. X-5. [pmid: 19088234].
140 Mendola P, Mannisto TI, Leishear K, et al. Neonatal health of infants born to mothers with asthma. J Allergy Clin Immunol. Jan. 2014;133(1):85-90.e1-4. X-2. [pmid: 23916153].
141 Merrill J, Phillips A, Keeling J, et al. Effects of automated immunization registry reporting via an electronic health record deployed in community practice settings. Appl Clin Inform. 2013;4(2):267-75. X-1, X-2, X-5. [pmid: 23874363].
142 Milani S, Buckler JM, Kelnar CJ, et al. The use of local reference growth charts for clinical use or a universal standard: a balanced appraisal. J Endocrinol Invest. Feb. 2012;35(2):224-6. X-2. [pmid: 22490992].
143 Miller PL, Frawley SJ, Sayward FG. Exploring three approaches for handling incomplete patient histories in a computer-based guideline for childhood immunization. Proc AMIA Symp. 1999:878-82. X-5 X-5. [pmid: 10566486].
144 Mitchell L. Connecting for children's health. Paediatr Nurs. Jul. 2005;17(6):24-5. X-2. [pmid: 16045001].
145 Mohr T. The second time around. Health Manag Technol. Sep. 4. 2008;29(9):22-5. X-2. [pmid: 18795739].
146 Moll HA. Clinical decision support systems in pediatrics: What are we waiting for?. [Dutch]. Tijdschrift voor Kindergeneeskunde. April. 2007;75(2):52-6. X-5.
147 Monteagudo-Piqueras O, Marin-Lopez J, Barragan Perez AJ, et al. The quality of diagnostic coding: a training need in primary care. Aten Primaria. May. 2013;45(5):282. X-2. [pmid: 23433704].
148 Nakamura MM, Harper MB, Jha AK. Change in adoption of electronic health records by US children's hospitals. Pediatrics. May. 2013;131(5):e1563-75. X-2, X-3, X-4. [pmid: 23589808].
149 Nielsen BA, Baum RA, Soares NS. Navigating ethical issues with electronic health records in developmental-behavioral pediatric practice. J Dev Behav Pediatr. Jan. 2013;34(1):45-51. X-2, X-5. [pmid: 23275058].
150 Nigrin DJ. When ‘hacktivists’ target your hospital. N Engl J Med. Jul. 31. 2014;371(5):393-5. X-2. [pmid: 25075830].
151 O'Connor AC, Kennedy ED, Loomis RJ, et al. Prospective cost-benefit analysis of a two-dimensional barcode for vaccine production, clinical documentation, and public health reporting and tracking. Vaccine. Jun. 28. 2013;31(31):3179-86. X-2. [pmid: 23664988].
152 Ostrowska-Nawarycz L, Nawarycz T, Derlecki S, et al. Application of computer base standards to pediatrics practice. Pol Merkur Lekarski. Sep. 2000;9(Suppl 1):46-8. X-2. [pmid: 11081346].
153 Otero P. Advantages and risks associated with the use of electronic medical records. Arch Argent Pediatr. Dec. 2011;109(6):476-7. X-2. [pmid: 22231883].
154 Paciorkowski N, Pruitt C, Lashly D, et al. Development of performance tracking for a pediatric hospitalist division. Hosp Pediatr. Apr. 2013;3(2):118-28. X-5. [pmid: 24340412].
155 Pageler NM, Longhurst CA, Wood M, et al. Use of electronic medical record-enhanced checklist and electronic dashboard to decrease CLABSIs. Pediatrics. Mar. 2014;133(3):e738-46. X-4. [pmid: 24567021].
156 Palma JP, Van Eaton EG, Longhurst CA. Neonatal Informatics: Information Technology to Support Handoffs in Neonatal Care. Neoreviews. 2011;2011(12). X-3, X-4. [pmid: 22199463].
157 Paperny DM. Computers and information technology: implications for the 21st century. Adolesc Med. Feb. 2000;11(1):183-202. X-2. [pmid: 10640346].
158 Pasek TA, Lefcakis LA, O'Malley CK, et al. Power in documentation: an eProgress note for APNs. Crit Care Nurse. Jun. 2. 2009;29(3):104-3. X-2. [pmid: 19487786].
159 Patel SJ, Longhurst CA, Lin A, et al. Integrating the home management plan of care for children with asthma into an electronic medical record. Jt Comm J Qual Patient Saf. Aug. 2012;38(8):359-65. X-5 X-. [pmid: 22946253].
160 Patel VN, Abramson E, Edwards AM, et al. Consumer attitudes toward personal health records in a beacon community. Am J Manag Care. Apr. 2011;17(4):e104-20. X-2, X-3. [pmid: 21774099].
161 Patwardhan A, Kelleher K, Cunningham D, et al. Improving the influenza vaccination rate in patients visiting pediatric rheumatology clinics using automatic best practice alert in electronic patient records. Pediatric Rheumatology. 13. Jul. 2012;10. X-7.
162 Pergami P, Thayapararajah SW, Seemaladinne N. West Virginia University Pediatric Stroke Registry: Clinical Description and Risk Factors Identification in Patients From a Rural Area. Clin Pediatr (Phila). 2014. Jul. 20. X-2. [pmid: 25049311].
163 Peverini RL, Beach DS, Wan KW, et al. Graphical user interface for a neonatal parenteral nutrition decision support system. Proc AMIA Symp. 2000:650-4. X-4, X-5. [pmid: 11079964].
164 Pevnick JM, Asch SM, Adams JL, et al. Adoption and use of stand-alone electronic prescribing in a health plan-sponsored initiative. Am J Manag Care. Mar. 2010;16(3):182-9. X-1, X-2. [pmid: 20225913].
165 Phillips RS. Accessing electronic information for clinical decisions. Arch Dis Child. Nov. 2000;83(5):373-4. X-2. [pmid: 11040137].
166 Pittman M. Loophole in alert system. Emerg Nurse. Mar. 2013;20(10):10. discussion. X-2. [pmid: 23586165].
167 Porcelli PJ, Rosenbloom ST. Evaluation of a neonatal growth curve designed for an electronic health record. AMIA Annu Symp Proc. 2006;1066. X-2. [pmid: 17238685].
168 Porter SC, Forbes P, Manzi S, et al. Patients providing the answers: narrowing the gap in data quality for emergency care. Qual Saf Health Care. Oct. 2010;19(5):e34. X-5 X-. [pmid: 20511242].
169 Potera C. A collaborative effort connects Delaware health system with local school nurses. Am J Nurs. Sep. 2014;114(9):17. X-2. [pmid: 25166233].
170 Potts AL, Barr FE, Gregory DF, et al. Computerized physician order entry and medication errors in a pediatric critical care unit. Pediatrics. Jan. 2004;113(1 Pt 1):59-63. X-2, X-3. [pmid: 14702449].
171 Pretorius E, Cronje ML, Strydom O. Development of a pediatric cardiac computer aided auscultation decision support system. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:6078-82. X-2. [pmid: 21097128].
172 Pyles LA, Hines C, Patock M, et al. Development of a web-based database to manage American College of Emergency Physicians/American Academy of Pediatrics Emergency Information Forms. Acad Emerg Med. Mar. 2005;12(3):257-61. X-5 X-. [pmid: 15741591].
173 Ramnarayan P, Britto J. Paediatric clinical decision support systems. Arch Dis Child. Nov. 2002;87(5):361-2. X-2. [pmid: 12390900].
174 Rappaport DI, Collins B, Koster A, et al. Implementing medication reconciliation in outpatient pediatrics. Pediatrics. Dec. 2011;128(6):e1600-7. X-2. [pmid: 22123872].
175 Rattay KT, Ramakrishnan M, Atkinson A, et al. Use of an electronic medical record system to support primary care recommendations to prevent, identify, and manage childhood obesity. Pediatrics. Jan. 2009;123(Suppl 2):S100-7. X-2. [pmid: 19088224].
176 Reckmann MH, Westbrook JI, Koh Y, et al. Does computerized provider order entry reduce prescribing errors for hospital inpatients? A systematic review. J Am Med Inform Assoc. Sep-Oct. 2009;16(5):613-23. X-3, X-4. [pmid: 19567798].
177 Rinke ML, Mikat-Stevens N, Saul R, et al. Genetic services and attitudes in primary care pediatrics. Am J Med Genet A. Feb. 2014;164a(2):449-55. X-5. [pmid: 24254914].
178 Rocca MA, Rosenbloom ST, Spooner A, et al. Development of a domain model for the pediatric growth charting process by mapping to the HL7 Reference Information Model. AMIA Annu Symp Proc. 2006;1077. X-2. [pmid: 17238696].
179 Roehrer E, Cummings E, Turner P, et al. Supporting cystic fibrosis with ICT. Stud Health Technol Inform. 2013;183:137-41. X-2. [pmid: 23388270].
180 Rudd S, Gemelas J, Reilley B, et al. Integrating clinical decision support to increase HIV and chlamydia screening. Prev Med. Dec. 2013;57(6):908-9. X-2. [pmid: 24120454].
181 Sainz de la Maza M, Molina N, Gonzalez-Gonzalez LA, et al. Clinical characteristics of a large cohort of patients with scleritis and episcleritis. Ophthalmology. Jan. 2012;119(1):43-50. X-1, X-2. [pmid: 21963265].
182 Schau CJ, Rokaw N. A path to medical excellence: steps to improve quality at Asheville Medicine and Pediatrics. N C Med J. May-Jun. 2014;75(3):184-5. X-2. [pmid: 24830491].
183 Schneck LH. Efficient, enterprising, electronic. Pediatric group stays current with technology. MGMA Connex. Nov-Dec. 2009;9(10):29-30. X-2. [pmid: 20058495].
184 Schulman J. NICU Notes: A Palm OS and Windows database software product and process to facilitate patient care in the newborn intensive care unit. AMIA Annu Symp Proc. 2003;999. X-2. [pmid: 14728502].
185 Senior T. Paper to EMR: A successful transition. Health Manag Technol. Oct. 2006;27(10):40. 2. 5. X-2. [pmid: 17052104].
186 Shaikh U, Nettiksimmons J, Bell RA, et al. Accuracy of parental report and electronic health record documentation as measures of diet and physical activity counseling. Acad Pediatr. Mar-Apr. 2012;12(2):81-7. X-5. [pmid: 22209035].
187 Sharifi M, Adams WG, Winickoff JP, et al. Enhancing the electronic health record to increase counseling and quit-line referral for parents who smoke. Acad Pediatr. Sep-Oct. 2014;14(5):478-84. X-2, X-5. [pmid: 25169159].
188 Shiffman RN, Brandt CA, Liaw Y, et al. A design model for computer-based guideline implementation based on information management services. J Am Med Inform Assoc. Mar-Apr. 1999;6(2):99-103. X-5 X-. [pmid: 10094062].
189 Shiffman RN, Liaw Y, Navedo DD, et al. User satisfaction and frustration with a handheld, pen-based guideline implementation system for asthma. Proc AMIA Symp. 1999:940-4. X-2. [pmid: 10566499].
190 Sigel E, Harpin SB, Tung G. Increasing Documentation and Referral for Youth at Risk for Violence Through the Primary Health Care Setting. Clin Pediatr (Phila). 2014. Oct. 9. X-2. [pmid: 25305258].
191 Simpson KR. Perinatal acuity tool. MCN Am J Matern Child Nurs. May-Jun. 2013;38(3):191. X-1, X-2, X-3, X-4. [pmid: 23625111].
192 Simpson LA. The adolescence of child health services research. JAMA Pediatr. Jun. 2013;167(6):509-10. X-2. [pmid: 23588790].
193 Sinha M, Khor KN, Amresh A, et al. The use of a kiosk-model bilingual self-triage system in the pediatric emergency department. Pediatr Emerg Care. Jan. 2014;30(1):63-8. X-5 X-. [pmid: 24378865].
194 Sittig DF, Ash JS, Zhang J, et al. Lessons from “Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system”. Pediatrics. Aug. 2006;118(2):797-801. X-3, X-4. [pmid: 16882838].
195 Sloane EB. Using a decision support system tool for healthcare technology assessments. IEEE Eng Med Biol Mag. May-Jun. 2004;23(3):42-55. X-2. [pmid: 15354994].
196 Smith SD. Cyber safety net. Minn Med. Nov. 2008;91(11):20-1. X-2. [pmid: 19108539].
197 Soderberg LM. Designing and creating a central venous catheter database and electronic charting system. J Intraven Nurs. May-Jun. 2001;24(3):159-68. X-2. [pmid: 11530361].
198 Soler D, Baldacchino D, Amato-Gauci A. Pilot of a Child Health Electronic Surveillance System (CHESS) in Malta. Journal of Public Health. June. 2007;15(3):199-209. X-2.
199 Spellman Kennebeck S, Timm N, Farrell MK, et al. Impact of electronic health record implementation on patient flow metrics in a pediatric emergency department. J Am Med Inform Assoc. May-Jun. 2012;19(3):443-7. X-3, X-4. [pmid: 22052897].
200 Spooner SA. We are still waiting for fully supportive electronic health records in pediatrics. Pediatrics. Dec. 2012;130(6):e1674-6. X-5 X-. [pmid: 23166347].
201 Starmer AJ, Duby JC, Slaw KM, et al. Pediatrics in the year 2020 and beyond: preparing for plausible futures. Pediatrics. Nov. 2010;126(5):971-81. X-2, X-5. [pmid: 20956424].
202 Sterling S, Kline-Simon AH, Wibbelsman C, et al. Screening for adolescent alcohol and drug use in pediatric health-care settings: predictors and implications for practice and policy. Addict Sci Clin Pract. 2012;7:13. X-2. [pmid: 23186254].
203 Stockwell DC, Bisarya H, Classen DC, et al. Development of an Electronic Pediatric All-Cause Harm Measurement Tool Using a Modified Delphi Method. J Patient Saf. 2014. Aug. 26. X-2, X-5. [pmid: 25162206].
204 Stockwell DC, Kirkendall E, Muething SE, et al. Automated adverse event detection collaborative: electronic adverse event identification, classification, and corrective actions across academic pediatric institutions. J Patient Saf. Dec. 2013;9(4):203-10. X-4. [pmid: 24257063].
205 Stuart K. You can't get there from here: misplaced incentives can undermine the goals of health care reform in the NICU setting. J Perinatol. Aug. 2012;32(8):570-3. X-5 X-. [pmid: 22842801].
206 Stultz JS, Porter K, Nahata MC. Sensitivity and specificity of dosing alerts for dosing errors among hospitalized pediatric patients. J Am Med Inform Assoc. Oct. 2014;21(e2):e219-25. X-2. [pmid: 24496386].
207 Subramanyan GS, Yokoe DS, Sharnprapai S, et al. An algorithm to match registries with minimal disclosure of individual identities. Public Health Rep. Jan-Feb. 1999;114(1):91-3. X-2. [pmid: 9925178].
208 Szende A. Ontario's province-wide paediatric electronic health record. Stud Health Technol Inform. 2009;143:99-103. X-2. [pmid: 19380922].
209 Szynal D. Continuity of kids' care. Health Data Manag. Apr. 2001;9(4):22-4. 6. X-2, X-5. [pmid: 11310339].
210 Taghon T, Elsey N, Miler V, et al. A medication-based trigger tool to identify adverse events in pediatric anesthesiology. Jt Comm J Qual Patient Saf. Jul. 2014;40(7):326-34. X-2. [pmid: 25130016].
211 Talmi A, Bunik M, Asherin R, et al. Improving developmental screening documentation and referral completion. Pediatrics. Oct. 2014;134(4):e1181-8. X-2. [pmid: 25180272].
212 Tan K, Dear PR, Newell SJ. Clinical decision support systems for neonatal care. Cochrane Database Syst Rev. 2005;(2). Cd004211. X-3, X-4. [pmid: 15846701].
213 Tarrago R, Nowak JE, Leonard CS, et al. Reductions in invasive device use and care costs after institution of a daily safety checklist in a pediatric critical care unit. Jt Comm J Qual Patient Saf. Jun. 2014;40(6):270-8. X-3, X-4. [pmid: 25016675].
214 Telleen S. Developing a state outcomes monitoring system in public health maternal and child health. J Med Syst. Jun. 1999;23(3):227-38. X-2. [pmid: 10554738].
215 Toll E. A piece of my mind. The cost of technology. Jama. Jun. 20. 2012;307(23):2497-8. X-2. [pmid: 22797449].
216 Toma TS, Rea MF. The Baby-Friendly Hospital Initiative and the computerized tools for its monitoring and sustainability. Rev Panam Salud Publica. Nov. 2011;30(5):505-6. X-3, X-4. [pmid: 22262280].
217 Trotter A, Maier L. Computerized physician order entry system in pediatric inpatients: Prevention of medication errors and adverse drug events. [German]. Monatsschrift fur Kinderheilkunde. February. 2009;157(2):160-5. X-5.
218 Tyler A, Boyer A, Martin S, et al. Development of a discharge readiness report within the electronic health record-A discharge planning tool. J Hosp Med. Aug. 2014;9(8):533-9. X-4. [pmid: 24825848].
219 Tyler-Beynum K, Jacobs BR. When less is more: big problem, small change, better outcomes. Pediatr Crit Care Med. May. 2013;14(4):439-40. X-4. [pmid: 23648877].
220 Upperman JS, Staley P, Friend K, et al. The introduction of computerized physician order entry and change management in a tertiary pediatric hospital. Pediatrics. Nov. 2005;116(5):e634-42. X-2. [pmid: 16263977].
221 Upperman JS, Staley P, Friend K, et al. The impact of hospitalwide computerized physician order entry on medical errors in a pediatric hospital. J Pediatr Surg. Jan. 2005;40(1):57-9. X-4. [pmid: 15868559].
222 Van Walleghem N, MacDonald CA, Dean HJ. Transition of care for young adults with type 1 and 2 diabetes. Pediatr Ann. May. 2012;41(5):e16-20. X-1, X-2. [pmid: 22587508].
223 Vardi A, Efrati O, Levin I, et al. Prevention of potential errors in resuscitation medications orders by means of a computerised physician order entry in paediatric critical care. Resuscitation. Jun. 2007;73(3):400-6. X-3, X-4. [pmid: 17289249].
224 Vargas-Herrera J, Manrique J, Nunez Mdel C, et al. Application of an electronic information system to the cervical cancer screening program. Rev Peru Med Exp Salud Publica. Jul. 2013;30(3):522-4. X-6. [pmid: 24100834].
225 Ventura ML, Battan AM, Zorloni C, et al. The electronic medical record: pros and cons. J Matern Fetal Neonatal Med. Oct. 2011;24(Suppl 1):163-6. X-3, X-4. [pmid: 21942617].
226 Verma SK. The information highway: a threat to medical confidentiality. Indian Pediatr. Aug. 2001;38(8):884-8. X-2. [pmid: 11520999].
227 Vest JR, Issel LM. Factors related to public health data sharing between local and state health departments. Health Serv Res. Feb. 2014;49(1 Pt 2):373-91. X-5 X-. [pmid: 24359636].
228 Wang Y, Caggana M, Sango-Jordan M, et al. Long-term follow-up of children with confirmed newborn screening disorders using record linkage. Genet Med. Oct. 2011;13(10):881-6. X-2. [pmid: 21637103].
229 Webber EC, Warhurst HM, Smith SS, et al. Conversion of a single-facility pediatric antimicrobial stewardship program to multi-facility application with computerized provider order entry and clinical decision support. Appl Clin Inform. 2013;4(4):556-68. X-2, X-4. [pmid: 24454582].
230 Weigle CG, Scanlon MC. There's many a slip. J Pediatr. Oct. 2006;149(4):435-6. X-2. [pmid: 17011307].
231 Weitzman M, Shiffman RN. Information technology and the future of child health care: a revolution is occurring. Arch Pediatr Adolesc Med. Sep. 2001;155(9):990-1. X-2. [pmid: 11529798].
232 West SL, Johnson W, Visscher W, et al. The challenges of linking health insurer claims with electronic medical records. Health Informatics J. Mar. 2014;20(1):22-34. X-1. [pmid: 24550563].
233 Wetzel G. Pediatric cardiology in a digital world. Curr Opin Cardiol. Jul. 2001;16(4):265-6. X-2, X-4. [pmid: 11574789].
234 Wong ST, Bernick LA, Portillo C, et al. Implementing a nurse information system in a nurse-managed primary care practice: a process in progress. Clin Excell Nurse Pract. Mar. 1999;3(2):123-7. X-1, X-2. [pmid: 10646401].
235 Woodman J, de Lusignan S, Rafi I, et al. GPs' role in safeguarding children. Bmj. 2012;345:e4758. X-2. [pmid: 22802403].
236 Worthey E, Bick D, Dimmock D, et al. Clinical diagnostic whole genome sequencing in a paediatric population: Experience from our WGS genetics clinic. BMC Proceedings. 01. Oct. 2012;6:S3. X-2.
237 Wu P, Carroll KN, Gebretsadik T, et al. The developmental trajectory of pediatric asthma in 3- to-10-year-olds. J Allergy Clin Immunol. May. 2012;129(5):1397-8. X-2. [pmid: 22322007].
238 Wu ST, Sohn S, Ravikumar KE, et al. Automated chart review for asthma cohort identification using natural language processing: an exploratory study. Ann Allergy Asthma Immunol. Nov. 2013;111(5):364-9. X-2. [pmid: 24125142].
239 Zarlengo R. Meaningful use for the pediatrician. Med Health R I. Jul. 2011;94(7):209-10. X-5. [pmid: 21894850].
240 Zerbe KJ, Allen JG. Integrating outcome measurement with clinical practice: the FACE Recording and Measurement System. Introduction. Bull Menninger Clin. Summer. 1999;63(3):285-7. X-1. [pmid: 10452191].
241 Zhai H, Brady P, Li Q, et al. Developing and evaluating a machine learning based algorithm to predict the need of pediatric intensive care unit transfer for newly hospitalized children. Resuscitation. Aug. 2014;85(8):1065-71. X-3, X-4. [pmid: 24813568].
242 Zhang Y, Levin JE, Padman R. Data-driven order set generation and evaluation in the pediatric environment. AMIA Annu Symp Proc. 2012;2012:1469-78. X-2, X-4. [pmid: 23304427].
243 Zhong VW, Pfaff ER, Beavers DP, et al. Use of administrative and electronic health record data for development of automated algorithms for childhood diabetes case ascertainment and type classification: the SEARCH for Diabetes in Youth Study. Pediatr Diabetes. 2014. Jun. 9. X-5 X-. [pmid: 24913103].
244 Zipkin R, Schrager SM, Keefer M, et al. Improving home management plan of care compliance rates through an electronic asthma action plan. J Asthma. Aug. 2013;50(6):664-71. X-5 X-. [pmid: 23574196].
245 Zomer-Kooijker K, van Erp FC, Balemans WA, et al. The expert network and electronic portal for children with respiratory and allergic symptoms: rationale and design. BMC Pediatr. 2013;13:9. X-2. [pmid: 23324209].
246 Zurhellen W. The coming of age of the electronic office. Pediatr Ann. May. 2001;30(5):289-97. X-2. [pmid: 11383469].