# Ongoing Studies

A search of ClinicalTrials.gov retrieved 46 records. The table below summarizes the records that were retained as relevant (n=17).

Search strategy: ((EHR) OR (EMR) OR (electronic AND record)) AND (functionality OR HIT OR CPOE OR “decision support” OR “electronic prescribing” OR “order entry” OR “information technology” OR “quality improvement”) | Child

Study Name Location Trial Identifier | Sponsors and Collaborators Study Status | Population Disease/Condition Age | Interventions / Groups | Outcomes
An Electronic Decision Support Tool to Improve Outpatient Asthma Care Children's Hospital of Philadelphia NCT01522144 | Agency for Healthcare Research and Quality (AHRQ) Children's Hospital of Philadelphia Completed Start: July 2006 Complete: August 2008 | - Children with a diagnosis of asthma; - Age 1 to18 years | Behavioral: Computerized decision support | Primary; - The proportion of patients on appropriate asthma controller medication at the end of the trial; Secondary; - an updated asthma action plan; - documentation of spirometry (6 to 18 years) in those with asthma; - an updated problem list that reflects an assessment of asthma severity
Better Pediatric Asthma Outcomes Through Chronic Care University of Connecticut Health Center NCT00355069 | University of Connecticut Health Center Agency for Healthcare Research and Quality (AHRQ) Completed Start: August 2001 Complete: May 2003 | - Determined by provider to be asthmatic; - Member of Medical Managed Care Organization partner group; - Ages 5 to 17 years | Behavioral: Electronic (computer based) provider feedback tool | Primary; - Asthma control; - Guideline appropriate medicating by providers; - Patient knowledge; Secondary; - Self-efficacy; - Social support
Child Health Improvement Through Computer Automation (CHICA) Highlighting Study IUMG Clinic System NCT01583101 | Indiana University Completed Start: April 2012 Complete: October 2012 | - Physicians practicing in one of our four study clinics who use CHICA | Other: Highlight set 1 (two prompts) Other: Highlight Set 2 (two different prompts) | - Whether or not prompt was answered
Comprehensive Clinical Decision Support (CDS) for the Primary Care of Premature Infants Children's Hospital of Philadelphia NCT01478711 | Children's Hospital of Philadelphia National Library of Medicine (NLM) Completed Start: September 2009 Complete: October 2012 | - Premature infants aged 20 weeks to 35 weeks | Other: Clinical Decision Support Tool | Primary; - Evaluate usability of the intervention; Secondary; - Evaluate effect on care process
Conversational IT for Better, Safer Pediatric Primary Care Boston Medical Center NCT01188629 | Boston Medical Center Agency for Healthcare Research and Quality (AHRQ) Active, not recruiting Start: July 2007 Complete: August 2011 | Parents of children will be enrolled in the study if they meet a set of eligibility criteria which includes:; - A primary care patient at Boston Medical Center; - An English speaking child and parent; - Ages 0 to 11 years | Behavioral: Safety Training Behavioral: Personal Health Partner and Counseling | Primary; - Personal Health Partner (PHP) assessment with electronic health record (EHR) data exchange before pediatric primary care visits; Secondary; - Personal Health Partner (PHP) pre-visit counseling with post-visit reinforcement
EHR-Based Clinical Decision Support to Improve BP Management in Adolescents HealthPartners Medical Group NCT01760239 | HealthPartners Institute for Education and Research National Heart, Lung, and Blood Institute (NHLBI) Recruiting Start: April 2014 Complete: August 2017 | - Pediatric and family medicine providers; - Ages 12 to 19 years | Behavioral: Clinical Decision Support | - Follow up of an elevated blood pressure within recommended interval; - Recognition of hypertension; - Appropriate workup for those with hypertension; - Appropriate Lifestyle Referral; - Costs of Care
Electronic Health Record (EHR) Decision Support to Improve Outpatient Asthma Care Children's Hospital of Philadelphia NCT00918944 | Children's Hospital of Philadelphia Agency for Healthcare Research and Quality (AHRQ) Completed Start: January 2006 Complete: August 2009 | - Known patients with asthma | Other: Control (passive EHR) Other: Intervention (interactive decision support system) | Primary; - Proportion of persistent asthmatic patients with at least one prescription for a controller medication in each period (baseline and intervention); Secondary; - Proportion of persistent asthmatic patients with; 1 an updated asthma action plan,; 2 spirometry as needed; 3 problem list with current asthma severity; 4 asthma-related quality of life scores; 5 absent school and work days.
Evaluation of a Shared Decision Making Portal for Pediatric Asthma Children's Hospital of Philadelphia NCT01715389 | Children's Hospital of Philadelphia Active, not recruiting Start: November 2012 Complete: November 2014 | - Parents/legal guardians of children aged 6 to12 years with persistent asthma, currently receiving chronic maintenance therapy, cared for at a study practice, with consistent access to a computer with an internet connection where they feel comfortable accessing MyChart (patient portal); - Clinician at study site | Other: MyAsthma Patient Portal | Primary; - Acceptability of the intervention to parents and clinicians; Secondary; - Shared decision making; - Parent Activation; - Goal Attainment; - Asthma-Related Quality of Life; - Asthma Control; - Asthma-related Utilization; - Asthma Medication Adherence/Receipt; - Feasibility of Recruitment; - Feasibility of Follow-up; - Feasibility of Portal Use
Giving Immunizations Through Vaccine Education Children's Hospital of Philadelphia NCT01159093 | Children's Hospital of Philadelphia Agency for Healthcare Research and Quality (AHRQ) Completed Start: May 2010 Complete: May 2011 | - All clinicians practicing at participating sites; - Parents with an eligible adolescent girl; - Adolescent girls aged 11 to 17 years; - Has a visit at one of the primary care centers within the last 15 months; - Has not completed the teen vaccine series | Behavioral: Family Decision Support (informational vaccine reminder telephone calls) Behavioral: Clinician Decision Support (an EHR-based decision support mechanism including reminders, education, audit and feedback on vaccination success) Other: Family Decision Support and Clinician Decision Support Other: Control | Primary; - Rate of HPV vaccination among girls actively cared for at participating sites; Secondary; - Rates of meningococcal and tetanus, diphtheria, and pertussis vaccines among girls in the study
Improving Otitis Media Care With Clinical Decision Support (OMHIT) Children's Hospital of Philadelphia NCT00581711 | Children's Hospital of Philadelphia (CHOP) Agency for Healthcare Research and Quality (AHRQ) Completed Start: December 2007 Complete: September 2010 | - All CHOP primary care and ENT practice sites with patients receiving care for otitis media; - Ages 2 months to 18 years | Other: 3-Part Intervention (A combination of training, an otitis media episode grouper, and clinical decision support) Other: 4-Part Intervention (A combination of clinician training, an otitis media episode grouper, clinical decision support, and feedback) Other: 1-part intervention (Provision of feedback on otitis media quality indicators) | Primary; - Quality of otitis media care; Secondary; - Clinician adoption of intervention and Resource Utilization
Improving Pediatric Safety and Quality With Health Care Information Technology Massachusetts General Hospital/Partners HealthCare NCT00134823 | Massachusetts General Hospital Agency for Healthcare Research and Quality (AHRQ) Completed Start: March 2005 Complete: September 2008 | - Partners-affiliated pediatric practice providers utilizing Longitudinal Medical Record (LMR), which is an electronic health record system. Also the parents of the patients of the above noted pediatric providers | Other: weight based dosing decision support | - Impact on rates of medication errors
Improving the Medication Management of Patients With Attention-Deficit Hyperactivity Disorder American Academy of Pediatrics NCT01769300 | American Academy of Pediatrics University of Colorado, Denver QED Clinical, Inc. Children's Hospital of Philadelphia Enrolling by invitation Start: January 2013 Complete: August 2014 | - Children aged 5 to12 years diagnosed with Attention-Deficit Hyperactivity Disorder (ADHD) | Behavioral: Clinical decision support for medication titration | Primary; - Improvement in symptoms, as measured by the parent-reported Vanderbilt Assessment Scale; Secondary; - Side effects as reported on the ADHD Vanderbilt Scale
Informing Policy to Implement Pediatric Family Engagement in Meaningful Use Stage 3 PROS PeRC NCT01966068 | Children's Hospital of Philadelphia Agency for Healthcare Research and Quality (AHRQ) American Academy of Pediatrics DARTNet Institute Recruiting Start: October 2013 Complete: September 2014 | - Child has a diagnosis of asthma on his/her problem list; - Ages 6 to 12 years | Other: MyAsthma Web Portal | Primary; - Use of the MyAsthma Portal Survey; Secondary; - Asthma management
Intervention to Improve Adherence in Teen Kidney Transplant Multiple sites NCT01356277 | McGill University Health Center Children's Hospital of Philadelphia Children's Hospital Medical Center, Cincinnati Seattle Children's Hospital Washington University Early Recognition Center British Columbia Children's Hospital The Hospital for Sick Children St. Justine's Hospital Recruiting Start: February 2012 Complete: June 2016 | - At least 3 months post kidney transplant; - Ages 11 to 24 years | Behavioral: Action-focused problem-solving Device: Electronic pillbox monitoring, dosage reminders, and feedback | - Taking adherence; - Timing adherence; - Clinical outcomes; - Healthcare system factors
PECARN Emergency Care Registry The Children's Hospital of Colorado Children's National Medical Center Cincinnati Children's Hospital Medical Center Children's Hospital of Philadelphia Data Coordinating Center NCT01657344 | Children's Hospital of Philadelphia Agency for Healthcare Research and Quality (AHRQ) Recruiting Start: January 2011 Complete: NR | - All patients (0-18) who registered in the ED during 2011 and during a 24 month study period between 2012 and 2015; - All licensed independent practitioners in the ED during 2011 and during a 24 month study period between 2012 and 2015; - Ages 18 years and younger | NR | Improved performance and decreased variability (variation) of care
Study of Technology to Accelerate Research Harvard Vanguard Medical Associates NCT01537510 | Harvard Pilgrim Health Care Brigham and Women's Hospital Cambridge Health Alliance Harvard Vanguard Medical Associates Completed Start: December 2010 Complete: September 2013 | - Child's BMI exceeds the 95th percentile for age and sex (CDC criteria); - Parent can respond to interviews and questionnaires in English; - Child has obtained well-child care from HVMA for at least the previous 15 months; - Ages 6 to 12 years | Behavioral: Usual Care Behavioral: Clinician intervention only Behavioral: Clinician intervention plus Direct-to-parent communication | Primary; - Change in screening and assessment of childhood obesity at the point of care, including BMI, blood pressure, and laboratory screening, and provision of nutrition and physical activity counseling; Secondary; - Change in Body Mass Index; - Change in Health Behaviors; - Costs (including clinician and family time) and cost-effectiveness in terms of children's change in BMI and weight-related behaviors